# Acknowledgments

The Research Team would like to acknowledge the following individuals for their contributions to this report: Claudia Bonnell, B.S.N., M.L.S., and Elaine Alligood, M.L.S., for literature searching and retrieval; Kathleen M. Ziegler, Pharm.D., for editorial input and assistance; Lisa Sarsany, M.A., for government project management; Sharon Flaherty, M.A., for Government contracts support; Lisa Garofalo for administrative support; and David Samson, M.S., for his useful and comprehensive advice.