# Discussion and Conclusions

Using the 2013 BCBSA TEC EPC evidence review, Screening for Methicillin-Resistant Staphylococcus aureus (MRSA),1 we developed an 11-step process for identifying and prioritizing clinically important research needs and research questions, with key input from a diverse group of stakeholders. The final research questions reflect the research needs in the evidence related to the key populations identified in the CER. Through this process, we propose a final list of seven research questions across three prioritized populations.

It should be noted that the Stakeholder Panel highlighted research needs that were outside the scope of the original review, such as the need to address methicillin-susceptible Staphylococcus aureus (MSSA). For example, in evaluating a screening strategy in surgical patients, it would be important to consider including MSSA, as certain interventions (i.e. decolonization with mupirocin/chlorhexidine) would target both infections. Strategies found to be effective in reducing HA MRSA infection would likely reduce HA MSSA, as well. By excluding MSSA, there will be a missed opportunity to target another major cause of surgical-site infections. This would also be relevant to pediatrics, as most hospitals see more nosocomial MSSA then MRSA in pediatric populations. Future study designs could prespecify MRSA and MSSA as different subgroups. Panel members brought forth the need for further basic epidemiological investigation to determine which groups are at high-risk for MRSA infection to help target and design appropriate interventions.

The Stakeholder Panel noted that at least two of the questions ranked of lower priority should be considered priority research needs. First, additional research is needed to address the most effective strategy for preventing MRSA infection among carriers after hospital discharge. This question has a high public health impact, and it may actually be one of the easier questions to assess in terms of developing an effective strategy for prevention. Similarly, the question addressing the most effective anatomical-site screening protocol for detecting MRSA and MSSA carriage especially in high-risk surgical patients is presently an “under-studied” area in need of further research.

There are several strengths to our process. First, it is important that panel members represented a wide range of relevant disciplines to ensure balanced and broad perspectives on research needs from the CER on this topic. Each stakeholder was highly interested and committed with high levels of participation at each step. The consumer/patient perspective was especially useful in drawing attention to the importance of screening as part of an effective MRSA control program. Specific issues brought forth by the consumer representative addressed who is at increased risk for MRSA infection, the focus of screening, and the economic impact of MRSA infections for patients and their caregivers as well as health care providers.

Second, given the breadth of potential topics, the introductory one-on-one calls with panelists helped establish the preliminary list of research needs. This made the first conference call with the Stakeholder Panel more productive. Third, the literature search update allowed for more informed decisions in selecting topics that were not duplicative with current ongoing trials and to which further research would add the greatest value. Given the multiple populations under study, it was helpful to the project team to organize the literature search update and stakeholder information according to the research needs identified in the CER that evolved into specific research questions. These themes allowed the team to cover more comprehensively aspects of disease management along the continuum of care, care settings, and populations. The project team also sought feedback from the stakeholders to identify key published studies and ongoing trials across the list of research needs.

Finally, the online survey instrument was very successful in prioritizing issues across a broad range of categories. When provided with information on available research, rankings by the Stakeholder Panel appeared to be based on the amenability to comparative effectiveness research. A number of stakeholders complimented our process. The panel members agreed that the final list of research needs and research questions covered key topics for future study on MRSA screening.

We encountered several challenges to our process. First, it was difficult to prioritize the research needs and associated research questions given their inter-relatedness. There were several ways to combine/categorize many of the proposed topics. There was overlap among various research needs and the key underlying research questions across the top-ranked research needs. The categorization depended on how the Stakeholder Panel wanted to approach different topic areas. For example, the proposed topics could be categorized either by different segments of the population (adult, pediatrics) or specific settings (e.g., surgical, ICU, ambulatory care/ED).

Second, it was difficult to propose appropriate types of study designs for the prioritized research questions given that these are broad-based questions with multiple components and outcomes. The Stakeholder Panel discussed the limitations of using cluster randomized controlled trials to study these questions especially with rare outcomes such as MRSA infection rates; a very large trial would be needed (in terms of the number of sites and clusters) to address such questions. Better quality before-and-after or quasi experimental studies at multiple sites may be able to address some of these KQs.

Third, it was important to maintain the focus on the research needs and scope addressed in the CER. The research questions were grouped by categories that could be linked to the CER scope, as the team had the evidence reviews and the updated literature search to back the findings. This always presents a challenge as evidenced by some of the topics brought up by the Stakeholder Panel listed in the previous paragraphs. Finally, one additional challenge or a limitation of this process was that the Stakeholder Panel was presented with the draft results of the CER during the prioritization process; the conclusions did change between the draft and the final report and thus the impact of these results on the rankings of the research needs is unknown.