# Survey Results of Research Questions

Rank | Research Questions | Total Votes^*^ | Weighted Score
1 | For surgical admissions, what is the most effective strategy for reducing HA-MRSA infection, morbidity, mortality and resource use? | 8 | 30
2 | In the intensive care setting, what is the most effective strategy for reducing MRSA infection rates, morbidity, mortality and resource use for patients with a positive MRSA culture? | 7 | 23
3 | What is the most effective strategy for preventing MRSA cross-transmission among high-risk surgical inpatients? | 5 | 18
4 | What is the most effective strategy for preventing MRSA cross-transmission among adult patients in the intensive care setting? | 4 | 17
5 | What factors are associated with increased risk of HA-MRSA infection among general medical adult inpatients? | 4 | 5
6 | What is the most effective strategy for preventing MRSA cross-transmission among general medical adult inpatients? | 3 | 13
7 | What is the most effective strategy for reducing MRSA infection rates, morbidity, mortality and resource use among general medical adult inpatients with a positive MRSA culture? | 3 | 7
8 | What is the most effective strategy for reducing CA-MRSA infection rates in patients who are admitted through ambulatory care/ER setting? | 3 | 6
9 | What is the most effective strategy for reducing MRSA infection and associated morbidity, mortality and resource use in pediatric inpatients? | 3 | 5
10 | What factors are associated with increased risk of MRSA infection in surgical inpatients? | 2 | 5
11 | What is the most effective strategy for preventing MRSA cross-transmission among pediatric inpatients? | 2 | 4
11 | What is the most effective strategy for managing patients with a positive MRSA screening test in the ambulatory care/ER setting with respect to morbidity, mortality, resource use and patient flow? | 2 | 4
13 | What is the most effective anatomical-site screening protocol (e.g., site(s), number of swabs etc.) for detecting MRSA among general medial adult inpatients? | 1 | 4
13 | What factors are associated with increased risk of HA-MRSA infection in the intensive care setting? | 1 | 4
15 | What is the most effective strategy for preventing MRSA infection among critically and chronically ill carriers after discharge from the hospital? | 1 | 3
16 | What is the most effective anatomical-site screening protocol (e.g., site(s), number of swabs etc.) for detecting MRSA in high-risk surgical inpatients? | 1 | 2
17 | What is the most effective anatomical-site screening protocol (e.g., site(s), number of swabs etc.) for detecting MRSA in adult patients in intensive care? | 0 | 0
18 | Who should be screened for MRSA in the ambulatory care/ER setting? | 0 | 0
19 | What is the most effective anatomical-site screening protocol (site(s), number of swabs etc.) for detecting MRSA in pediatric inpatients? | 0 | 0

* Responses from 10 (of 10) panel members