# Survey Results of Research Needs

Rank | Research Needs | Total Votes^*^ | Weighted Score
1 | What are the central components of a MRSA screening strategy? | 10 | 30
2 | Who may benefit from MRSA screening? | 9 | 35
2 | What outcomes should be considered for evaluations of MRSA screening? | 9 | 35
4 | What are the most effective tests for MRSA screening? | 9 | 18
5 | What factors could influence MRSA test results (e.g., when to screen, which sites to swab)? | 7 | 19
6 | What are the appropriate comparators for MRSA screening? | 4 | 8
7 | Which study perspectives should be considered for evaluations of MRSA screening (e.g., societal, hospital, patient, payer)? | 2 | 5

* Responses from 10 (of 10) panel members