# List of Research Needs

Research Needs | Draft CER | Stakeholder Panel Comments | Primary Studies | Ongoing Clinical Trials^*^
Who may benefit from MRSA screening? (Population/Setting) | - Evidence is inconclusive due to the variation in the clinical context in which screening has been evaluated.; - Higher risk populations e.g., ICU or inpatient surgical patients are likely to derive the most benefit.; - Factors that may affect the applicability of results from either targeted or broad-based screening include:; ○ Individual risk of acquisition or colonization of MRSA.; ○ Variations in practice and in MRSA carriage and infection rates across geographic regions and individual institutions. | - Who is “high risk”?; ○ No clear definitions. Prevalence studies may be helpful.; ○ Many children with MRSA infection would not be considered high risk.; - For pediatrics, screening on hospital admission is impractical because high prevalence of MRSA colonization in the community will yield very large numbers; targeting specific hospital populations may be more manageable e.g., ICU populations. It would be very difficult to perform multicenter studies.; - Universal vs. targeted screening? Do we need universal screening of inpatients? ‘Do you own the infections of your roommate’? | Provided by Stakeholder Panel:; - Milstone AM. MRSA colonization and risk of subsequent infection in critically ill children: importance of preventing nosocomial MRSA transmission. Clin Infect Dis. 2011 Nov;53:853–9.; - Fritz SA. The natural history of contemporary Staphylococcus aureus nasal colonization in community children. Pediatr Infect Dis J. 2011 Apr;30:349–51.; - Walsh EE. Sustained reduction in MRSA wound infections after cardiothoracic surgery. Arch Intern Med. 2011;171:68–73. | [underlined: NCT Number]: NCT00980980 Title: Cluster Randomized Trial of Hospitals to Assess Impact of Targeted Versus Universal Strategies to Reduce MRSA in Intensive Care Units (ICUs) [REDUCE-MRSA] Recruitment: Completed (no results). URL: ClinicalTrials.gov/show/NCT00980980
What are the most effective tests for MRSA screening? (Interventions) What factors could influence MRSA test results? (Timing) | - Findings:; ○ Variation in the screening methodology and reporting standards limit applicability of results.; - Recommendations:; ○ Examine each element of an intervention bundle to accurately determine the benefit or harm that can be attributed to it.; ○ Transparent and thorough reporting of all transmission prevention strategies and decolonization therapy deployed with screening.; ○ Uniformity in testing strategy used (e.g., PCR vs. culture), test turnaround time, and the handling of patients while awaiting lab results.; ○ Account for compliance with infection control strategies.; ○ Accounting for the management of patients before screening test results are known. | - Benefit of MRSA screening depends on the overall rationale of the screening strategy, as it is often coupled with other infection control strategies; - Compliance will depend on what motivates practitioners, e.g., skepticism about its usefulness, need for quality data.; - Logistics of screening:; ○ Which site(s)? There are no data correlating screening to specific sites of infection.; ○ Not all community infections colonize nasally; pediatrics commonly colonized in other areas, (e.g., perineal).; ○ How many sites to swab?; ○ How many swabs/site?; ○ When to screen? e.g., should elective admissions be screened 7–10 days prior to admission to avoid delays? | - Haith L. Evaluation of nasal MRSA polymerase chain reaction (PCR) as a screening tool in burn center patients. Surgical Infections 2012;13:S36.; Provided by Stakeholder Panel:; - Gurieva T. The successful Veterans Affairs initiative to prevent MRSA Infections revisited. Clin Infect Dis. 2012 Apr 4:1618–20. | None identified
What are the appropriate comparators for MRSA screening? (Comparators) | - Systematic review included “no screening” or “targeted screening” as comparators. | - Other infection control practices should be considered viable comparators, because new data suggest non-screening strategies using chlorhexidine bathing or universal gown/glove may be effective at reducing transmission and decolonization rates (See Mastering hOSpital Antimicrobial Resistance (MOSAR) network studies). | - Derde LP. Chlorhexidine body washing to control antimicrobial-resistant bacteria in intensive care units: a systematic review. Intensive Care Med 2012 Apr 12.; - Tatokoro M. Successful control of MRSA in a urology ward possibly due to avoidance of antimicrobial prophylaxis in minimally invasive surgery: Our 11 years trial. Journal of Urology 2012;187:e24.; Provided by Stakeholder Panel:; - Fritz SA. Household versus individual approaches to eradication of community-associated Staphylococcus aureus in children: a randomized trial. Clin Infect Dis. 2012 Mar;54:743–51. | [underlined: NCT Number]: NCT00976638 Title: Clinical Trial to Reduce Antibiotic Resistance in European Intensive Cares (MOSAR-ICU) Status: Completed (no results) URL: ClinicalTrials.gov/show/NCT00976638 [underlined: NCT Number]: NCT00685867 Title: Two Strategies for Methicillin-resistant Staphylococcus Aureus (MRSA) Infection Prevention in Surgical Patients (MOSAR-04) Status: Unknown URL: http://ClinicalTrials.gov/show/NCT00685867 [underlined: NCT Number]: NCT01127516 Title: The Causes and Interpretation of Low-level Resistance in Staphylococcus Aureus Status: Completion, May 2013 URL: http://ClinicalTrials.gov/show/NCT01127516
What outcomes should be considered in evaluation of MRSA screening? (Outcomes) | - Precise estimates of the impact of screening for MRSA-carriage on morbidity and mortality are needed.; - Harms of screening must be clearly delineated. | - From an ER perspective what is the impact of rapid testing strategies on patient flow and bed flow?; ○ A backlog can result in negative outcomes outside the ER e.g., delays in care, ambulance transfers or diversions to other facilities and patients dying ‘en route’.; ○ Extended boarding if hospital isolation beds are not available, etc.; - What do you do with patients who screen positive, culture results are not available and isolation rooms may be in short supply or when it is difficult to get a specimen?; ○ Patients on precautions checked on less often.; ○ Adherence to infection control practices.; ○ Patient satisfaction and emotional wellbeing.; - Research should take into account the emotional, financial and health loss of the patient. | | None identified

* Literature search update covering March 1, 2012 through May 15, 2012

Broad-based Issues | Draft CER | Stakeholder Panel Comments
Improvement in the quality of evidence supporting MRSA screening. | Recommendations; - Use of the cluster RCT rather than before-after designs adequately powered to detect effect on outcome.; ○ Large multicenter trials needed.; - RCTs must adequately control for bias and confounding owing to epidemiologic trends, concomitant infection prevention strategies and account for compliance with interventions.; - Maximally transparent reporting of:; ○ Interventions and potential confounders.; ○ Transmission prevention strategy and the use of decolonization therapy. | - The impact of MRSA screening will depend on setting, rationale for screening and patient populations.; - Need to focus on % total staph aureus infections, including MSSA, as the individual rates may differ substantially across institutions.; - Need to standardize research approaches and use ecologically-controlled designs over the traditional before-after observational designs.; - Need for a definition of MRSA “outbreak”.; - Need to account for the impact of multi-drug resistant pathogens and inter-hospital patient sharing as a mechanism of disease transmission.; - Research should focus on who should get screened, how often, and how long to isolate and cohort patients when we are uncertain how long they may have been infected.; - How do improved patient outcomes and associated costs link back to a screening program when multiple components may be involved?; - The first priority is preventing MRSA infection. Failing that, early identification of potential MRSA infection is important.; - Data are lacking on effective strategies that respond to a positive culture e.g., decolonization vs. prevention of transmission.; - Meaningful pay for performance programs are needed that will reduce health care-associated infection rates, especially MRSA and surgical site infections, and associated mortality and morbidity.; - Community-acquired infections should also be considered.

## Other topics posed by Stakeholder Panel

- MRSA screening in prevention of MRSA lung infections.
- Use of MRSA screening results to predict who is at risk for MRSA lung infection.

## Additional References Provided by Stakeholder Panel for Further Perspective/To Guide Future MRSA Studies

1 Bode LGM. Preventing surgical-site infections in nasal carriers of Staphylococcus aureus. N Engl J Med. 2010;362:9-17. [pmid: 20054045].
2 Fritz SA. Effectiveness of measures to eradicate Staphylococcus aureus carriage in patients with community-associated skin and soft-tissue infections: A randomized trial. Infection Control and Hospital Epidemiology. 2011;32:872-880. [pmid: 21828967].
3 Kim DH. Institutional prescreening for detection and eradication of MRSA in patients undergoing elective orthopaedic surgery. J Bone Joint Surg Am. 2010;92:1820-1826. [pmid: 20610773].
4 Kirkland KB. Taking off the gloves: Toward a Less Dogmatic Approach to the Use of Contact Isolation. Clin Infect Dis. 2009;48:766-71. [pmid: 19196174].
5 Liu C. The bundled approach to MRSA surgical site infection prevention: Is the whole greater than the sum of its parts?. Arch Intern Med. 2011;171(1):73-74. [pmid: 21220664].
6 Wertheim HFL. Mupirocin prophylaxis against nosocomial Staphylococcus aureus infections in nonsurgical patients: A randomized study. Ann Intern Med. 2004;140:419-425. [pmid: 15023707].