# Survey Tool Used To Rate Research Questions

## Instructions to fill the survey

The objective is to rate the research questions based on pre-specified criteria by using a voting mechanism. Please read the following instructions carefully before proceeding with your voting.

Instructions:

- There are in total 19 research questions
- Each panel member has been allotted a total of 5 votes.
- Choose and rank questions in the order of your perceived importance with a score of 1 representing the highest importance and 5 representing lower importance.

Please cast your votes based on the following criteria:

- Current importance
- Potential for significant health impact
- Incremental value
- Feasibility

You can review these criteria in detail [below].

## Prioritization Criteria for Research Questions

### Current importance

- Incorporates both clinical benefits and harms
- Represents important variation in clinical care due to controversy/uncertainty regarding appropriate care
- Addresses high costs to consumers, patients, health-care systems, or payers
- Utility of available evidence limited by changes in practice, e.g., disease detection

### Potential for significant health impact

- Potential for significant health impact:
  ○ To improve health outcomes
  ○ To reduce significant variation related to quality of care
  ○ To reduce unnecessary burden on those with health-care problems
- Potential for significant economic impact, reducing unnecessary or excessive costs
- Potential for evidence-based change
- Potential risk from inaction, i.e., lack of evidence for decision-making produces unintended harms
- Addresses inequities, vulnerable populations, patient subgroups with differential impact (e.g., by age)

### Incremental value

- Adds useful new information to existing portfolio of research on topic OR
- Validates existing research when body of evidence is scant

### Feasibility

- Factors to be considered:
  ○ Interest among researchers
  ○ Duration
  ○ Cost
  ○ Methodological complexity (e.g., do existing methods need to be refined?)
  ○ Implementation difficulty
  ○ Facilitating factors
  ○ Potential funders

(Criteria modified for primary research from: Whitlock EP et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health-Care program. Journal of Clinical Epidemiology 2010; 63: 491–501)

[underlined: *Please rank your top 5 research questions from 1 to 5 with 1 having the highest priority and 5 the lowest.]

1. What factors are associated with increased risk of MRSA infection in surgical inpatients?
2. What is the most effective strategy for preventing MRSA cross-transmission among adult patients in the intensive care setting?
3. What is the most effective strategy for preventing MRSA infection among critically and chronically ill carriers after discharge from the hospital?
4. What is the most effective anatomical-site screening protocol (e.g., site(s), number of swabs etc.) for detecting MRSA in adult patients in intensive care?
5. What factors are associated with increased risk of HA-MRSA infection among general medical adult inpatients?
6. What is the most effective strategy for reducing MRSA infection and associated morbidity, mortality and resource use in pediatric inpatients?
7. What is the most effective strategy for preventing MRSA cross-transmission among high-risk surgical inpatients?
8. Who should be screened for MRSA in the ambulatory care/ER setting?
9. What is the most effective strategy for preventing MRSA cross-transmission among general medical adult inpatients?
10. What is the most effective anatomical-site screening protocol (e.g., site(s), number of swabs etc.) for detecting MRSA among general medial adult inpatients?
11. What is the most effective strategy for reducing MRSA infection rates, morbidity, mortality and resource use among general medical adult inpatients with a positive MRSA culture?
12. What factors are associated with increased risk of HA-MRSA infection in the intensive care setting?
13. What is the most effective anatomical-site screening protocol (e.g., site(s), number of swabs etc.) for detecting MRSA in high-risk surgical inpatients?
14. What is the most effective anatomical-site screening protocol (site(s), number of swabs etc.) for detecting MRSA in pediatric inpatients?
15. What is the most effective strategy for preventing MRSA cross-transmission among pediatric inpatients?
16. What is the most effective strategy for managing patients with a positive MRSA screening test in the ambulatory care/ER setting with respect to morbidity, mortality, resource use and patient flow?
17. What is the most effective strategy for reducing CA-MRSA infection rates in patients who are admitted through ambulatory care/ER setting?
18. For surgical admissions, what is the most effective strategy for reducing HA-MRSA infection, morbidity, mortality and resource use?
19. In the intensive care setting, what is the most effective strategy for reducing MRSA infection rates, morbidity, mortality and resource use for patients with a positive MRSA culture?

If you have any further comments please give them below:

______________________________________________________________________________