# Survey Tool Used To Rate Research Needs

## Instructions to fill the survey

The objective is to rate the research needs based on pre-specified criteria by using a voting mechanism. Please read the following instructions carefully before proceeding with your voting.

Instructions:

- There are in total 7 research needs
- Each panel member has been allotted a total of 5 votes.
- Choose and rank gaps in the order of your perceived importance with a score of 1 representing the highest importance and 5 representing lower importance.

Please cast your votes based on the following criteria:

- Current importance
- Potential for significant health impact
- Incremental value
- Feasibility

You can review these criteria in detail [below].

## Prioritization Criteria for Research Needs

### Current importance

- Incorporates both clinical benefits and harms
- Represents important variation in clinical care due to controversy/uncertainty regarding appropriate care
- Addresses high costs to consumers, patients, health-care systems, or payers
- Utility of available evidence limited by changes in practice, e.g., disease detection

### Potential for significant health impact

- Potential for significant health impact:
  ○ To improve health outcomes
  ○ To reduce significant variation related to quality of care
  ○ To reduce unnecessary burden on those with health-care problems
- Potential for significant economic impact, reducing unnecessary or excessive costs
- Potential for evidence-based change
- Potential risk from inaction, i.e., lack of evidence for decision-making produces unintended harms
- Addresses inequities, vulnerable populations, patient subgroups with differential impact (e.g., by age)

### Incremental value

- Adds useful new information to existing portfolio of research on topic OR
- Validates existing research when body of evidence is scant

### Feasibility

- Factors to be considered:
  ○ Interest among researchers
  ○ Duration
  ○ Cost
  ○ Methodological complexity (e.g., do existing methods need to be refined?)
  ○ Implementation difficulty
  ○ Facilitating factors
  ○ Potential funders

(Criteria modified for primary research from: Whitlock EP et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health-Care program. Journal of Clinical Epidemiology 2010; 63: 491–501)

[underlined: *Please rank your top 5 research needs from 1 to 5 with 1 having the highest priority and 5 the lowest.]

1. What factors could influence MRSA test results (e.g., when to screen, which sites to swab)?
2. Who may benefit from MRSA screening?
3. What are the most effective tests for MRSA screening?
4. What are the central components of a MRSA screening strategy
5. What are the appropriate comparators for MRSA screening?
6. What outcomes should be considered for evaluations of MRSA screening?
7. Which study perspectives should be considered for evaluations of MRSA screening (e.g., societal, hospital, patient, payer)?

If you have any further comments please give them below:

______________________________________________________________________________