# Search Strategies for Updating of Evidence

## PUBMED on 5/14/2012

“Methicillin-Resistant Staphylococcus aureus”[Mesh] AND ((“2012/03/01”[PDat] : “2012/06/31”[PDat]))

Limits: Humans, English, published in the last year

OR

Methicillin-Resistant Staphylococcus aureus AND ((“2012/03/01”[PDat] : “2012/06/31”[PDat]))

OR

(“Methicillin Resistance” AND “Staphylococcus aureus”) OR “methicillin-resistant staphylococcus aureus” OR MRSA AND ((“2012/03/01”[PDat] : “2012/06/31”[PDat]))

AND

randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized controlled trials[mh] OR random allocation[mh] OR double-blind method[mh] OR single-blind method[mh] OR clinical trial[pt] OR clinical trials[mh] OR “clinical trial” OR ((singl* OR doubl* OR trebl* OR tripl*) AND (mask* OR blind*)) OR placebos[mh] OR placebo* OR random* OR research design[mh:noexp] OR follow-up studies[mh] OR prospective studies[mh] OR prospectiv* OR volunteer* OR “Comparative Study “[Publication Type] OR “Evaluation Studies “[Publication Type] OR control OR controlled OR controls OR comparative study[tiab] OR comparative[title]

Results: 11 Studies

## EMBASE.COM on 5/14/2012

‘mrsa’/exp OR mrsa OR ‘methicillin resistance’/exp OR ‘methicillin resistance’

OR

‘methicillin’/exp

OR

methicillin AND resistan* AND staphylococcus*

AND

randomized AND controlled AND trial OR controlled AND clinical AND trial* OR randomized AND controlled AND trials OR random AND allocation OR ‘double blind’ AND ‘method’/exp OR ‘single blind’ AND ‘method’/exp OR clinical AND trial OR clinical AND trials OR ‘clinical trial’/exp OR (singl* OR doubl* OR trebl* OR tripl* AND (mask* OR blind*)) OR ‘placebos’/exp OR placebo* OR random* OR ‘follow up’/exp AND studies OR prospective AND studies OR prospectiv* OR ‘comparative study’/exp OR ‘evaluation’/exp AND studies OR controlled OR comparative AND ‘study’/exp OR comparative:ti

Results: 19 Studies

## Cochrane Central on 4/28/2012

methicillin-resistant staphylococcus aureus OR ‘methicillin resistance AND staphylococcus aureus OR MRSA

Results: 1 new trial in the CCTR

## Clinical Trials.Gov

methicillin-resistant staphylococcus aureus

OR

methicillin resistance AND staphylococcus aureus

OR

MRSA

Results: 26 recently updated trial records