# Summary of Evidence From Draft Comparative Effectiveness Review

Key Questions | Outcome | # of Studies^§^ | Reference | # of Subjects | B | C | D | P | Overall Grade
KQ1 Universal screening vs. No screening | MRSA Transmission | 1 QEX | Jain 2011^1^ | 1,934,598 | H | U | N | N | Insufficient
KQ1 Universal screening vs. No screening | MRSA Infection | 2 QEX | Robicsek 2008^2^> Jain 2011^1^ | 112,985 1,934,598 | M | Y | Y | N | Insufficient
KQ1 Universal screening vs. No screening | MRSA Bacteremia or Blood Stream Infection | 2 QEX | Robicsek 2008^2^ Jain 2011^1^ | 112,985 1,934,598 | M | Y | Y | N | Insufficient
KQ1 Universal screening vs. No screening | MRSA Surgical Site Infection | 1 QEX | Robicsek 2008^2^ | 112,985 | L | U | Y | N | Insufficient
KQ1 Universal screening vs. No screening | Morbidity, Mortality, Harms, Resource Utilization | 0 | NA | No studies | NA | NA | NA | NA | Insufficient
KQ2 Universal screening vs. Targeted Screening | MRSA Transmission | 0 | NA | No studies | NA | NA | NA | NA | Insufficient
KQ2 Universal screening vs. Targeted Screening | MRSA Infection | 2 QEX | Robicsek 2008^2^ Leonhardt 2011^3^ | 128,334 | M | N | Y | N | Insufficient
KQ2 Universal screening vs. Targeted Screening | Morbidity, Mortality, Harms, Resource Utilization | 0 | NA | No studies | NA | NA | NA | NA | Insufficient
KQ3A Screening of ICU Risk Pts Vs No Screening | MRSA Transmission | 1 RCT | Huskins 2011^4^ | 4,056 | M | N | N | N | Insufficient
KQ3A Screening of ICU Risk Pts Vs No Screening | MRSA Transmission | 3 QEX | Holzmann-Pazgal 2011^5^ Huang 2006^6^ Raineri 2007^7^ | 3,097 Unclear 21,754; (166,877^‡^) | M | N | N | N | Insufficient
KQ3A Screening of ICU Risk Pts Vs No Screening | MRSA Infection | 1 QEX | Robicsek 2008^2^ | Unclear | L | U | Y | N | Insufficient
KQ3A Screening of ICU Risk Pts Vs No Screening | MRSA Bacteremia or Blood Stream Infection | 2 QEX | Robicsek 2008^2^ Huang 2006^6^ | Unclear | M | N | Y | N | Insufficient
KQ3A Screening of ICU Risk Pts Vs No Screening | MRSA Surgical Site Infection | 1 QEX | Robicsek 2008^2^ | Unclear | L | U | Y | N | Insufficient
KQ3A Screening of ICU Risk Pts Vs No Screening | Morbidity, Mortality, Harms, Resource Utilization | 0 | No studies | NA | NA | NA | NA | NA | Insufficient
KQ3B Screening of Surgical Pts Vs No Screening | MRSA Transmission | 1 QEX-XR | Harbarth 2008^30^ | 21,754 | L | U | N | N | Insufficient
KQ3B Screening of Surgical Pts Vs No Screening | MRSA infection | 1 QEX-XR | Harbarth 2008^8^ | 21,754 | M | N | Y | N | Insufficient
KQ3B Screening of Surgical Pts Vs No Screening | MRSA infection | 1 QEX | Muder 2008^9^ | 21,449^‡^ | M | N | Y | N | Insufficient
KQ3B Screening of Surgical Pts Vs No Screening | MRSA Surgical Site Infection | 1 QEX-XR | Harbarth 2008^8^ | 21,754 | M | N | Y | N | Insufficient
KQ3B Screening of Surgical Pts Vs No Screening | MRSA Surgical Site Infection | 1 QEX | Muder 2008^9^ | 21,449^‡^ | M | N | Y | N | Insufficient
KQ3B Screening of Surgical Pts Vs No Screening | Morbidity, Mortality, Harms, Resource Utilization | 0 | No Studies | NA | NA | NA | NA | NA | Insufficient
KQ3C Screening of High Risk Pts Vs No Screening | MRSA Transmission | 2 QEX | Rodriguez-Bano 2010^10^ Ellingson 2011^11^ | Unclear | H | U | N | N | Insufficient
KQ3C Screening of High Risk Pts Vs No Screening | MRSA Infection | 1 QEX | Harbarth 2000^12^ | 506,012 | H | U | Y | N | Insufficient
KQ3C Screening of High Risk Pts Vs No Screening | MRSA Bacteremia/Blood Stream Infection | 3 QEX | Rodriguez-Bano 2010^10^ Chowers 2009 Ellingson 2011^11^ | Unclear 377,945; (1,535,806^‡^) Unclear | H | Y | Y | N | Insufficient
KQ3C Screening of High Risk Pts Vs No Screening | MRSA Surgical Site Infection | 1 QEX | Harbarth 2000^12^ | 506,012 | H | U | Y | N | Insufficient
KQ3C Screening of High Risk Pts Vs No Screening | Morbidity, Mortality, Harms, Resource Utilization | 0 | No Studies | NA | NA | NA | NA | NA | Insufficient
KQ4 Expanded screening vs. Limited Screening | MRSA Transmission | 1 QEX | Rodriguez-Bano 2010^10^ | Unclear | H | U | N | N | Insufficient
KQ4 Expanded screening vs. Limited Screening | MRSA Infection | 1 QEX | Chaberny 2008^14^ | 219,124; (1,987,676^‡^) | H | U | N | N | Insufficient
KQ4 Expanded screening vs. Limited Screening | MRSA Bacteremia | 1 QEX | Rodriguez-Bano 2010^10^ | Unclear | H | N | Y | N | Insufficient
KQ4 Expanded screening vs. Limited Screening | Morbidity, Mortality, Harms, Resource Utilization | 0 | No Studies | NA | NA | NA | NA | NA | Insufficient

Note: This table lists the findings from the draft CER report; the conclusions have changed between the draft and the final report.

B: Risk of bias; C: Consistency; D: Directness; H: High; P: Precision, NA: not applicable; N: No; QEX: quasi experimental; RCT: randomized controlled trial; U: Unknown; Y: Yes; XR: cross over.

§ CCS Studies;

‡ Patient days

## References

1 Jain R, Kralovic SM, Evans ME, et al. Veterans Affairs initiative to prevent methicillin-resistant Staphylococcus aureus infections. N Engl J Med. 04. 14. 2011;364(15):1419-30. [pmid: 21488764].
2 Robicsek A, Beaumont JL, Paule SM, et al. Universal surveillance for methicillin-resistant Staphylococcus aureus in 3 affiliated hospitals. Ann Intern Med. 03. 18. 2008;148(6):409-18. [pmid: 18347349].
3 Leonhardt KK, Yakusheva O, Phelan D, et al. Clinical effectiveness and cost benefit of universal versus targeted methicillin-resistant Staphylococcus aureus screening upon admission in hospitals. Infect Control Hosp Epidemiol. 2011;32(8):797-803. [pmid: 21768764].
4 Huskins WC, Huckabee CM, O'Grady NP, et al. Intervention to reduce transmission of resistant bacteria in intensive care. N Engl J Med. 04. 14. 2011;364(15):1407-18. [pmid: 21488763].
5 Holzmann-Pazgal G, Monney C, Davis K, et al. Active surveillance culturing impacts methicillin-resistant Staphylococcus aureus acquisition in a pediatric intensive care unit. Pediatr Crit Care Med. 2011;12(4):e171-e5. [pmid: 20838355].
6 Huang SS, Yokoe DS, Hinrichsen VL, et al. Impact of routine intensive care unit surveillance cultures and resultant barrier precautions on hospital-wide methicillin-resistant Staphylococcus aureus bacteremia. Clin Infect Dis. 10. 15. 2006;43(8):971-8. [pmid: 16983607].
7 Raineri E, Crema L, De Silvestri A, et al. Meticillin-resistant Staphylococcus aureus control in an intensive care unit: a 10 year analysis. J Hosp Infect. 12. 2007;67(4):308-15. [pmid: 17945395].
8 Harbarth S, Fankhauser C, Schrenzel J, et al. Universal screening for methicillin-resistant Staphylococcus aureus at hospital admission and nosocomial infection in surgical patients. JAMA. 2008;299(10):1149-57. [pmid: 18334690].
9 Muder RR, Cunningham C, McCray E, et al. Implementation of an industrial systems-engineering approach to reduce the incidence of methicillin-resistant Staphylococcus aureus infection. Infect Control Hosp Epidemiol. 2008 Aug;29(8):702-8, 7 p following 8.
10 Rodriguez-Bano J, Garcia L, Ramirez E, et al. Long-term control of endemic hospital-wide methicillin-resistant Staphylococcus aureus (MRSA): the impact of targeted active surveillance for MRSA in patients and healthcare workers. Infect Control Hosp Epidemiol. 08. 2010;31(8):786-95. [pmid: 20524852].
11 Ellingson K, Muder RR, Jain R, et al. Sustained reduction in the clinical incidence of methicillin-resistant Staphylococcus aureus colonization or infection associated with a multifaceted infection control intervention. Infect Control Hosp Epidemiol. 01. 2011;32(1):1-8. [pmid: 21133794].
12 Harbarth S, Martin Y, Rohner P, et al. Effect of delayed infection control measures on a hospital outbreak of methicillin-resistant Staphylococcus aureus. J Hosp Infect. 09. 2000;46(1):43-9. [pmid: 11023722].
13 Chowers MY, Paitan Y, Gottesman BS, et al. Hospital-wide methicillin-resistant Staphylococcus aureus control program: a 5-year follow-up. Infect Control Hosp Epidemiol. 08. 2009;30(8):778-81. [pmid: 19580437].
14 Chaberny IF, Schwab F, Ziesing S, et al. Impact of routine surgical ward and intensive care unit admission surveillance cultures on hospital-wide nosocomial methicillin-resistant Staphylococcus aureus infections in a university hospital: an interrupted time-series analysis. J Antimicrob Chemother. 12. 2008;62(6):1422-9. [pmid: 18765411].