# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BCBSA TEC EPC: Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (BCBSA TEC EPC)
CER: Comparative Effectiveness Review
ED: Emergency department
EHC: Effective Health Care
EPC: Evidence-based Practice Center
HA: Hospital-acquired
ICU: Intensive care unit
MRSA: Methicillin-Resistant Staphylococcus aureus
MSSA: Methicillin-Susceptible Staphylococcus aureus
PCR: Polymerase chain reaction
PICOTS: Population(s), interventions, comparators, outcomes, timing, settings
RCT: Randomized controlled trial
U.S.: United States