# Results

## Recently Published Studies and Ongoing Trials

### Published Studies

Of the 212 abstracts reviewed, 30 articles were chosen for inclusion: 12 address research Gap 1; nine address Gap 2; and another nine address Gap 3 (see Appendix Table A1 for citations and brief descriptions). Two articles relevant to Gap 1 were added after final review of the table by the TEPP members; one was recommended by a TEPP member and the other was published while this report was being written.

During the initial one-on-one telephone conversations, several TEPP members also recommended two studies published in the New England Journal of Medicine in March 2009.^3,4^ These articles examine the impact of PSA screening on prostate cancer mortality, among other outcomes, and initially might not appear to address the gaps identified in the initial Minnesota CER. However, these articles raise the issue of whether early detection of prostate cancer —and early treatment—reduces death from prostate cancer. Thus, they are relevant to Gap 1 identified by the TEPP, “Identifying Which Patients to Treat.”

Schroeder et al.3 is a very large (n=162,387) multicenter, European randomized trial designed to evaluate the effect of screening on death rates from prostate cancer, with screening conducted at approximately 4-year intervals. The median follow-up period was 9 years. More prostate cancers were detected in the screening group (8.2% vs. 4.8%). The proportion of men with cancer with a Gleason score of 7 or more was 27.8% in the screening group and 45.2% in the control group. Mortality rates began to diverge after 7 to 8 years and continued to do so. The adjusted (for interim analyses) rate ratio for death from prostate cancer in the screening group versus the control group was 0.80 (95% confidence interval [CI]: 0.65–0.95, p=0.01). To prevent one prostate-cancer death, 1,410 (95% CI: 1,142–1,721) men would need to be screened and 48 additional subjects would need to be treated. Limitations of this study include the fact that protocols differed by country, e.g., PSA cutoff value, age, use of digital rectal examination (DRE). In particular, some countries randomized patients before informed consent, so patients knew assignments before agreeing to participate (and were more compliant with screening).

Andriole et al.4 was a large (n=76,693) multicenter trial in the United States to determine the effect of annual PSA testing and digital rectal examination (DRE) versus usual care on mortality from prostate cancer. Patients were enrolled between 1993 and 2000, and the median follow-up period was 11.5 years. There were few deaths from prostate cancer at 7 to 10 years and no significant difference between study groups (rate ratio=1.13; 95% CI: 0.75–1.70). The majority of prostate cancers were stage 2 at diagnosis with a Gleason score of 5 to 6. Compliance with screening was about 85% in the intervention group (annual PSA for 6 years; DRE for 4 years). In the control group, PSA testing increased from 40% in year 1 to 52% in year 6; and ranged from 41% to 46% for DRE. As noted in the correspondence following publication of this study, this study therefore is actually a comparison of higher versus lower levels of PSA screening, rather than an evaluation of annual PSA testing versus none.

Together, the studies by Schroeder et al.3 and Andriole et al.4 suggest that the benefit of PSA screening for preventing prostate-cancer related deaths may be small or nonexistent. They also raise the question of overtreatment of patients whose cancer was detected through PSA screening, given that according to the Schroeder et al.3 study, 1,410 men would need to be screened and 48 additional subjects would need to be treated to prevent a single prostate-cancer death. Evaluating these studies and related literature is beyond the scope of this project. However, the publication of these studies between the publications of the Minnesota EPC CER and the current project may have shifted the TEPP members’ focus from how to treat to who and when to treat. TEPP members agreed that the first step is to identify whom to treat, then to decide how to treat them (i.e., comparative effectiveness of specific treatments), and finally to address racial and ethnic disparities and physician-patient decisionmaking. The latter cannot be adequately addressed without knowing the answers to the first questions.

Most of the other articles that address Gap 1, primarily retrospective studies and prospective prognostic analyses, focus on active surveillance and predictors of disease progression. Three issues evident in the active surveillance studies are that a number of men switch to active treatment in the absence of disease progression, that death from causes other than prostate cancers exceed those from prostate cancer itself, and that longer follow-up periods are needed (see, e.g., Klotz et al. 2010^5^). Several other studies examined predictors of disease progression or severity, including PSA-based measures (e.g., Radwan et al. 2007,6 Freedland et al. 2008^7^) and MRI findings.8 A study of men with PSA levels below 4 ng/mL at diagnosis indicated that while these men are at relatively low risk, high-grade disease is still found within this group.9

The studies identified relating to Gap 2 include comparative studies of alternative treatments for prostate cancer: four RCTs10–13 and several other types of studies, including patient surveys.14–16 However, the follow-up from any of these studies is not long enough to provide data on long-term outcomes. The studies on Gap 3 primarily address the impact of surgeon volume or other characteristics on treatment outcomes. Several studies by Vickers and colleagues suggest a definite learning curve for various types of radical prostatectomy.17–19 Another study suggests that the specialty of the physician a patient sees after diagnosis has a strong impact on the treatment selected.20 Additional details on all of these studies are found in Appendix Table A1.

### Ongoing Trials

The review of localized prostate cancer trials at ClinicalTrials.gov yielded 13 trials of potential relevance for this pilot project. The most important trials, also mentioned by several TEPP members, are the PIVOT trial in the United States, with initial results expected in about 1 year, and the ProtecT trial in the United Kingdom, with initial results expected in about five years. In each trial, participants were randomized to one of several treatments, including either watchful waiting or active surveillance. In the ProtecT trial, enrollees were initially randomized to PSA screening and then those in whom prostate cancer was detected were randomized to treatment. These trials address Gap 1, particularly through examination of the active-surveillance arm, and Gap 2, by gauging the comparative effectiveness of surgery versus radiation therapy versus conservative management for patients with localized prostate cancer. Given the time, effort, and cost required for these trials and the fact that they are already underway, TEPP members agreed that similar trials should not be initiated. Eight other studies comparing treatments (Gap 2) are also underway, although most of them are more limited in scope (for citations and brief summaries, see Appendix Table A2). For example, they may not focus on all major treatment options or examine only a limited set of outcomes such as health-related quality of life. The three studies addressing Gap 1 focus on predictors of more aggressive disease, although in one case the population is limited to men undergoing radiation therapy. Only one trial on treatment decisionmaking was included for Gap 3. There are additional studies on patient education but with less of a focus on joint patient-physician decisionmaking.

## Prioritization of Research Gaps

As noted in the Methods section, after the first conference call TEPP members were asked to rate the proposed research gaps. Both the preliminary results based on six responses presented to the TEPP in preparation for the second conference call and the more complete results based on 9 responses are found in Appendix B. During the second conference call, members noted that the numerical sums for each research gap were relatively similar, except for the lowest ranked research gap and to a lesser degree, the highest ranked gap. While BCBSA TEC EPC staff questioned whether a different rating system should have been used, TEPP members noted that the close scores might have been due to the overlap between the different gaps. Following this discussion, BCBSA TEC EPC staff reorganized the research gaps into 3 larger categories. TEPP members endorsed this approach via email and on the last conference call. They edited some titles, moved one research gap to another category, and decided not to use the PICOS categories for this task.

The final three research gaps, in priority order, are identifying which patients to treat, the comparative effectiveness of alternative treatments for localized prostate cancer, and factors with an impact on treatment decisionmaking. During the last conference call, the TEPP members added a fourth research gap, called “Methodologic challenges,” which transcends prostate cancer and applies to other important research areas as well. This late addition was not ranked.

The final, prioritized list of research gaps is shown in Table 4. The content of the gaps is largely consistent with the Minnesota CER but regrouped into fewer categories. In addition, several research gaps were added (noted in list), and the fourth gap on methodologic challenges is new.

Table 4 Prioritized list of research gaps on treatments for localized prostate cancer, 2010

Gap 1: Identifying which patients to treat; ▪ Identifying which patients to treat (e.g., those most likely to have aggressive cancer) and when; ▪ Understanding of the natural history of localized prostate cancer in the PSA era; ▪ Identifying biomarkers to provide reliable estimates about prostate cancer aggressiveness and the relative effectiveness of treatments
Gap 2: Comparative effectiveness of different treatments for localized prostate cancer; ▪ Comparing alternative treatment strategies such as surgery, radiotherapy, androgen-deprivation therapy (ADT), or active surveillance; ▪ Acquiring better evidence on advanced technologies such as IMRT, proton beam radiation, laparoscopic and robotic-assisted prostatectomy, high-intensity focused ultrasound, cryotherapy. Ideally, these should be compared to established treatments; ▪ Comparing alternative strategies within a given modality, e.g., laparoscopic vs. open prostatectomy or intensity-modulated radiotherapy vs. brachytherapy (Added by TEPP); ▪ Obtaining better evidence on outcomes of treatment for patient subgroups (e.g., age, comorbidities, disease characteristics, racial/ethnic groups, including disparities)
Gap 3: Factors with impact on treatment decisionmaking; ▪ Incorporating physician and patient preferences into treatment decisions; ▪ Investigating treatment patterns by physician characteristics (e.g., specialty, years in practice, volume) or institutional characteristics (e.g., tertiary vs. community hospital); ▪ Understanding patient psychology in dealing with uncertainty regarding screening, diagnosis, and treatment, especially for active surveillance choice (Added by TEPP)
Gap 4: Methodologic challenges (NOTE: TEPP members noted that this gap applies more broadly than prostate cancer research. It was not prioritized with the other three gaps.); ▪ Exploring approaches to deal with potential “contamination” of RCTs as participants choose screening or treatments over the course of the trial that are not consistent with the arm to which they have been randomized; ▪ Developing and applying more sophisticated statistical and methodologic techniques for dealing with observational data

## Recommended Research Studies

### Prioritization of Recommended Research

As described in the Methods section, during the second conference call the TEPP members began brainstorming ideas for research studies to address the proposed research gaps, then refined them, and finally prioritized them via email after the last conference call. The results of the prioritization process are shown in Table 5. The maximum potential score for a study varies with the total number of studies under each research gap. For example, there are 5 studies under Gap 1, so the maximum score for a study is 5. Summed over the 11 members responding, the maximum score for a study under Gap 1 is 55. Also, the studies address the gap generally and do not correspond to the bulleted points under each gap in Table 5.

Table 5 Potential research studies, prioritized for each research gap (n=11 of 11)

Research Gap to be Addressed (in order or priority, except for Gap 4; see note below) | Proposed Research Study (Detailed descriptions after table)
Gap 1: Identifying which patients to treat (Maximum possible score=55) | Project 1.1. Identify predictors of disease progression (score=49)
Gap 1: Identifying which patients to treat (Maximum possible score=55) | Project 1.2. Standardize protocols used for patients on active surveillance (score=30)
Gap 1: Identifying which patients to treat (Maximum possible score=55) | Project 1.3a. Facilitate future research on potential biomarkers to identity patients whose disease is likely to be aggressive (score=29 [TIE])
Gap 1: Identifying which patients to treat (Maximum possible score=55) | Project 1.3b. Evaluate whether all patients with elevated PSA scores warrant immediate biopsy (score=29 [TIE])
Gap 1: Identifying which patients to treat (Maximum possible score=55) | Project 1.5. Investigate more accurate and reliable methods of identifying grade of disease after biopsy (score=28)
Gap 2: Comparative effectiveness of different treatments for localized prostate cancer (Maximum possible score=33) | Project 2.1. Comparative effectiveness of alternative treatments within a modality such as surgery or radiation therapy (score=26)
Gap 2: Comparative effectiveness of different treatments for localized prostate cancer (Maximum possible score=33) | Project 2.2a. Evaluate frequency of use of ADT for low-risk prostate cancer (score=20 [TIE])
Gap 2: Comparative effectiveness of different treatments for localized prostate cancer (Maximum possible score=33) | Project 2.2b Long-term sequelae of treatments for localized prostate cancer (score=20 [TIE])
Gap 3: Factors with an impact on treatment decisionmaking (Maximum possible score=33) | Project 3.1. Evaluate patient preferences and perceptions of risk in selecting prostate cancer treatment (score=23)
Gap 3: Factors with an impact on treatment decisionmaking (Maximum possible score=33) | Project 3.2. Increasing use of shared decisionmaking between physicians and patients (score=22)
Gap 3: Factors with an impact on treatment decisionmaking (Maximum possible score=33) | Project 3.3. Study the psychological impact of diagnosis and treatment, especially for those under active surveillance (score=21)
Gap 4: Methodologic challenges (Maximum possible score=22) | Project 4.1. Exploring methods to increase patient adherence with randomization scheme (score=19)
Gap 4: Methodologic challenges (Maximum possible score=22) | Project 4.2. Increasing the use of statistical modeling and other advanced methods in studies on localized prostate cancer (score=14)

NOTE: Gaps 1–3 are listed in order of priority, as established by the TEPP. Gap 4 was added on the last conference call and was not prioritized as a research gap. It applies to a large range of clinical issues, extending beyond treatments for localized prostate cancer. However, the two projects under Gap 4 were prioritized.

- The most highly ranked project to address Gap 1 is to identify predictors of disease progression. Furthermore, the score assigned to this project (49) stands out from the scores assigned to the rest of the projects under Gap 1 (28–30). These projects address the need for standardized protocols for patients on active surveillance and standardized approaches to grading disease; creating a data infrastructure that will facilitate evaluation of potentially useful biomarkers; and evaluating when biopsies should be performed in response to elevated PSA levels.
- For Gap 2, the top-ranked project addresses the comparative effectiveness of alternative treatments within a modality such as surgery or radiotherapy (Project 2.1; score=26). It is followed by a study on the use of androgen deprivation therapy among men with low risk cancer (Project 2.2a; score=20) which is tied with a study on the long-term sequelae of the treatments themselves (Project 2.2b; score=20).
- For Gap 3, the top-ranked project focuses on evaluating patient preferences and perceptions of risk in selecting treatment (Project 3.1; score=23), followed by increasing use of shared decisionmaking between patients and physicians (Project 3.2; score=22) and studying the psychological impact on patients of diagnosis and treatment (Project 3.3; score=21).
- Finally, the projects under Gap 4 on exploring methods to increase patient adherence with randomization (Project 4.1) and increasing use of statistical modeling and other advanced methods to studies on localized prostate cancer (Project 4.2) were ranked 19 and 14, respectively.

### Description of Recommended Research

The specific research projects are described in more detail in the following section. They are rank ordered and the PICOS framework is used to describe each study.

Proposed Projects to Address Gap 1: Identifying Which Patients To Treat

(Maximum possible study score=55)

Project 1.1. Identify predictors of disease progression (score=49)
[underlined: Context:] | Active surveillance has become a more common option for men recently diagnosed with localized prostate cancer, as it has become clear that many of these cancers are indolent and are unlikely to have a substantial negative impact on a patient’s quality of life before that patient dies of other causes. However, there is a subset of patients with aggressive disease for whom postponing treatment might increase the likelihood of death from prostate cancer. The ability to identify those patients with aggressive disease a priori is a prerequisite to expanding the proportion of men with newly diagnosed, low-risk prostate cancer who undergo active surveillance, especially among somewhat younger otherwise healthy men.
[underlined: Design:] | Prospective registry with clinical data at diagnosis and treatment, and follow-up outcome data. A biospecimen repository would allow analyses of novel biomarkers in the future.
[underlined: Population:] | Patients with localized prostate cancer diagnosed in PSA era
[underlined: Intervention:] | Active surveillance
[underlined: Comparator:] | None (or other prostate cancer treatments, if registry is broadened to include all newly diagnosed, localized prostate cancer patients)
[underlined: Outcomes:] | Timing of treatment; intermediate outcomes such as PSA failure or bone metastases; patient preferences regarding treatment throughout the period; health- related quality of life (HRQOL)
[underlined: Setting:] | Multi-institutional
[underlined: Other:] | Need to collect comprehensive data on patient risk factors (those related to the disease, such as perineural invasion or inflammation, as well as comorbidities) and preferences. Might also issue Request for Proposals for ideas on how best to analyze these data.
Project 1.2. Standardize protocols used for patients on active surveillance (score=32)
[underlined: Context:] | As the awareness that many men diagnosed with prostate cancer are overtreated and suffer the adverse events associated with prostate cancer therapies with little or no effect on survival, there has been increased interest in the use of active surveillance. Active surveillance differs from watchful waiting in that there may be more frequent follow up with blood tests (to measure PSA), biopsies, and diagnostic imaging, along with an often prespecified threshold for initiating treatment. However, protocols for active surveillance often vary across physicians or institutions. Identifying optimal protocols may benefit patients; introducing consistency across sites will also facilitate the conduct of meta-analyses in the future.
[underlined: Design:] | Prospective randomized controlled trials or registries focusing on frequency and timing of followup (e.g., PSA tests, biopsy, imaging), timing and indications for treatment
[underlined: Population:] | Patients with localized prostate cancer in PSA era
[underlined: Intervention:] | Active surveillance
[underlined: Comparator:] | Alternative active surveillance regimens
[underlined: Outcomes:] | Disease progression, time to treatment, treatment outcomes, quality of life, patient preferences
[underlined: Setting:] | Multi-institutional
Project 1.3a. Facilitate future research on potential biomarkers to identity patients whose disease is likely to be aggressive (score=29 [TIE])
[underlined: Context:] | Although many efforts have been made to predict which patients with localized prostate cancer have aggressive disease, existing tools are inadequate to predict which patient to treat with any high degree of accuracy. With the emergence of biomarkers in other diseases, such as breast cancer, that have both prognostic and predictive power, the search continues to identify biomarkers that can predict which patients with prostate cancer face a poorer prognosis and may benefit to a greater degree from immediate treatment. Although a number of biomarkers have been explored to date with limited success, there continues to be potentially important role for biomarkers.
[underlined: Design:] | Establish biospecimen repositories with clinical data on diagnosis, treatment, and follow-up
[underlined: Population:] | Patients with localized prostate cancer diagnosed in PSA era
[underlined: Intervention:] | Collecting tumor, serum, and urine specimens as well as clinical data
[underlined: Comparator:] | None
[underlined: Outcomes:] | Time to progression, disease-specific and overall survival
[underlined: Setting:] | Prospective studies of localized prostate cancer
[underlined: Other:] | Biospecimen repositories create the resources needed to test the use of novel biomarkers in the future, while providing long-term data on outcomes that would take a long time to collect. Such repositories are being established for other studies, such as the ProtecT trial in the United Kingdom. While expensive to create and maintain, additional repositories would allow for more biomarker testing, particularly since tissue specimens are finite. In addition, given the differences in treatment regimens, populations, and possibly outcomes across studies, biospecimens from different trials might help address alternative hypotheses. The National Cancer Institute is establishing methods for each step of the process for creating and maintaining biospecimen repositories.
Project 1.3b. Evaluate whether all patients with elevated PSA scores warrant immediate biopsy (score=29 [TIE])
[underlined: Context:] | Concern is increasing about the overtreatment of men with prostate cancer, particularly among older men who may be far more likely to die of other illnesses than prostate cancer. However, once a biopsy is performed and cancer is diagnosed, it is more difficult for patients to forego therapy and choose, for example, active surveillance. A diagnosis of cancer confers a level of anxiety in many patients that is difficult to ignore. Furthermore, although PSA screening has become widely used in the United States for cancer screening, PSA is an indicator of tissue differentiation and not necessarily of prostate cancer. One possible way to address the issue of overtreatment is to delay biopsies rather than acting immediately when PSA-related metrics indicate potential cancer.
[underlined: Design:] | Prospective randomized controlled trial
[underlined: Population:] | Patients with elevated PSA scores on screening
[underlined: Intervention:] | Immediate biopsy
[underlined: Comparator:] | Delayed biopsy performed based on PSA velocity. Might also vary PSA cutpoints for making decisions about immediate biopsy or delayed biopsy by adding additional study arms.
[underlined: Outcomes:] | Cancer detection, disease progression, patient preferences
[underlined: Setting:] | Multi-institutional
[underlined: Other:] | Once a person is diagnosed with cancer, it is difficult for them to forego treatment. In other cases in which overtreatment is suspected (e.g., cervical cancer), RCTs have been conducted to gauge the impact of delaying biopsy (e.g., the ALTS trial; see http://dcp.cancer.gov/programs-resources/groups/bgcrg/alts/centers).
Project 1.5. Investigate more accurate and reliable methods of identifying grade of disease after biopsy (score=28)
[underlined: Context:] | There appears to be substantial variation in the diagnosis and staging of prostate cancer, as evidence by so-called creep in Gleason scores (with higher scores for the same type of case). The inability to distinguish consistently among patients with newly diagnosed, localized prostate cancer who have indolent versus aggressive disease may also lead to overtreatment of many patients with indolent disease. Given the substantial adverse events associated with the treatment of prostate cancer, identifying biomarkers or other indicators of indolent disease would enable many more patients to be followed using active surveillance, thus avoiding or postponing the need to undergo treatment.
[underlined: Design:] | Observational; may also use specimens from prior RCTs
[underlined: Population:] | Patients undergoing biopsy for possible prostate cancer
[underlined: Intervention:] | Alternative metrics for diagnosing prostate cancer, including objective criteria to produce standardized pathology interpretations (to address variation in Gleason scores) and testing biomarkers that may predict disease progression.
[underlined: Comparator:] | Current methods for diagnosing prostate cancer
[underlined: Outcomes:] | Inter-rater and inter-institutional reliability, disease progression, treatment outcomes (progression-free survival [PFS], overall survival [OS])
[underlined: Setting:] | Multi-institutional

Proposed Projects to Address Gap 2: Comparative Effectiveness of Different Treatment for Localized Prostate Cancer

(Maximum possible score=33)

Project 2.1. Comparative effectiveness of alternative treatments within a modality such as surgery or radiation therapy (score=26)
[underlined: Context:] | Large randomized controlled trials comparing surgery, radiotherapy, and either active surveillance or watchful waiting are currently underway. Results are expected in about 1 year for the PIVOT trial and in 5 and 10 years for the ProtecT trial. Given the difficulty of randomizing prostate cancer patients to widely different treatments in the United States and the length of follow-up needed, the TEPP did not recommend the initiation of another trial of this type but rather focused on trials of treatments within a type of therapy (e.g., one type of surgery or radiation versus another over a shorter period of time with a primary focus on HRQOL). Many of these alternative types of surgery and radiation therapy, as well as newer techniques such as cryotherapy or high-intensity focused ultrasound are being used without evidence on comparative effectiveness.
[underlined: Design:] | RCT
[underlined: Population:] | Patients with recently diagnosed localized prostate cancer
[underlined: Intervention:] | Treatments for prostate cancer
[underlined: Comparator:] | Alternative treatments within a modality such as surgery (e.g., robotic-assisted laparoscopic prostatectomy vs. open radical prostatectomy) or radiation therapy (e.g., intensity-modulated radiation therapy vs. proton beam).
[underlined: Outcomes:] | Adverse events, HRQOL over 5–8 years; time to recurrence (although follow-up unlikely to be long enough to permit reliable estimates); cost-effectiveness of more expensive technologies
[underlined: Setting:] | Multi-institutional. Include different types of facilities (e.g., academic medical centers and community hospitals) and physicians with varying experience and training.
Project 2.2a. Evaluate frequency of use of androgen-deprivation therapy (ADT) for low-risk prostate cancer (score=20 [TIE])
[underlined: Context:] | The use of androgen deprivation therapy is associated with substantial adverse events, including the risk of cardiac disease, and has a negative impact on patients’ HRQOL. Evidence has shown that it improves long-term prostate cancer outcomes for patients with intermediate- and high-risk disease but not for those with low-risk disease. There is concern that low-risk individuals, especially older men, continue to be treated.
[underlined: Design:] | Physician survey or analysis of combined registry and claims data. This could also be developed as a randomized, controlled trial of the use of ADT versus delayed ADT
[underlined: Population:] | Patients with low-risk, localized prostate cancer
[underlined: Intervention:] | ADT
[underlined: Comparator:] | No use of ADT
[underlined: Outcomes:] | Frequency of ADT, outcomes of ADT
[underlined: Setting:] | Multi-institutional. Include different types of facilities (e.g., academic medical centers and community hospitals) and physicians with varying experience and training, if possible.
Project 2.2b. Long-term sequelae of treatments for localized prostate cancer (score=20 [TIE])
[underlined: Context:] | Treatments for localized prostate cancer, including surgery and radiotherapy, can have long-term sequelae independent of the disease itself. These include late radiation effects, second cancers, and adverse effects that interact with consequences of aging or other comorbid disease. While the PIVOT and PROTECT trials will provide some useful information, they do not cover all treatment options (e.g., different types of radiotherapy). It is feasible to collect data on 10-year follow-up, for techniques used after the widespread adoption of PSA testing in the United States. Since some of these treatment effects may not emerge for 20 years, longer term follow-up will be needed as well.
[underlined: Design:] | Longitudinal, cohort study
[underlined: Population:] | Patients treated for low-risk, localized prostate cancer
[underlined: Intervention:] | Any treatment for prostate localized cancer
[underlined: Comparator:] | Other treatments for prostate cancer or active surveillance
[underlined: Outcomes:] | Adverse events such as urinary and fecal incontinence, erectile dysfunction, unrelated cancer (which may or may not be related to treatment)
[underlined: Setting:] | Multi-institutional. Include different types of facilities (e.g., academic medical centers and community hospitals) and physicians with varying experience and training, if possible.

Proposed Projects To Address Gap 3: Factors With an Impact on Treatment Decisionmaking

(Maximum possible score=33)

Project 3.1. Evaluate patient preferences and perceptions of risk in selecting prostate cancer treatment (score=23)
[underlined: Context:] | It has long been known that individual’s perceptions of risk and decisions made upon them are not purely “rational,” in that they are not based on a simple calculation of the likelihood and magnitude of risk. In an area like prostate cancer, the issue is complicated by a substantial degree of uncertainty regarding who should be treated and what the outcomes of alternative treatments for a given patient will be. In understanding patients’ treatment decisionmaking, it is therefore important to know more about patient preferences and perceptions of risk and how they weigh adverse effects of treatment versus chance for benefit.
[underlined: Design:] | Survey pre- and post-treatment
[underlined: Population:] | Patients with recently diagnosed localized prostate cancer
[underlined: Intervention:] | Any treatment for localized prostate cancer and active surveillance
[underlined: Comparator:] | Alternative treatment or active surveillance
[underlined: Outcomes:] | Patients’ preferences, perceptions of risk, and treatment choices; comparisons of how these may change before and after treatment
[underlined: Setting:] | Multicenter with different types of institutions and physicians
Project 3.2. Increasing use of shared decisionmaking between physicians and patients (score=22)
[underlined: Context:] | A variety of decision aids have been developed and tested for selecting treatments for prostate cancer, due to the uncertainties regarding treatment efficacy and the trade-offs among adverse events associated with different treatments. However, to date, it does not appear that these approaches are used routinely in clinical practice.
[underlined: Design:] | Compare different approaches to incorporating decision aids and shared decisionmaking into clinical practice
[underlined: Population:] | Clinics treating patients with recently diagnosed localized prostate cancer
[underlined: Intervention:] | To be defined
[underlined: Comparator:] | To be defined
[underlined: Outcomes:] | Use of decision aids, impact on treatment choices, factors that facilitate or serve as barriers to adoption of these tools
[underlined: Setting:] | Multicenter with different types of institutions
Project 3.3. Study the psychological impact of diagnosis and treatment, especially for those under active surveillance (score=21)
[underlined: Context:] | Recent studies of men under active surveillance for localized prostate cancer have shown that a number undergo treatment because of personal preference, rather than any sign of disease progression. Some men with elevated PSAs but negative biopsies also have been reported to experience considerable distress. While men under active surveillance may avoid the potential adverse effects of treatment, they live with the knowledge of having untreated prostate cancer.
[underlined: Design:] | Survey pre- and post-treatment (length of followup to be specified)
[underlined: Population:] | Patients with recently diagnosed localized prostate cancer undergoing treatment or in active surveillance
[underlined: Intervention:] | Any treatment for localized prostate cancer and active surveillance
[underlined: Comparison:] | Across treatments and active surveillance
[underlined: Outcomes:] | Measures of psychological well-being
[underlined: Setting:] | Multicenter with different types of institutions

Proposed Projects to Address Gap 4: Methodologic Challenges

(Maximum possible score=22)

Project 4.1. Exploring methods to increase patient adherence with randomization scheme (score=19)
[underlined: Context:] | Trials of cancer screening in the United States have shown that some individuals in the control group undergo screening on their own (e.g., Andriole et al. 2009). If it occurs frequently enough, this unplanned crossing over of patients to a different trial arm may alter the question that can be addressed by the study. Similar patterns may occur with treatment trials, in which for example, an individual on active surveillance may seek treatment before any signs of disease progression emerge. Information on why patients change their minds and whether any approaches are effective in reducing this phenomenon are needed.
[underlined: Design:] | Surveys to help understand participants’ decisionmaking; measuring the effectiveness of approaches intended to reduce this unplanned crossing over
[underlined: Population:] | Patients with newly diagnosed, low-risk prostate cancer
[underlined: Intervention:] | To be defined
[underlined: Comparator:] | No intervention
[underlined: Outcomes:] | Nonadherence with randomization assignment
[underlined: Setting:] | Multicenter with varying types of institutions and conditions.
Project 4.2. Increasing the use of statistical modeling and other advanced methods in studies on localized prostate cancer (score=14)
[underlined: Context:] | It is often difficult to conduct randomized trials on the major questions of interest, because of their cost and complexity, and particularly when there are a variety of questions about a treatment protocol. Statistical work is being done on ways to replicate some of the advantages of a randomized controlled trial using observational data.21,22 The increasing use of statistical modeling, instrumental variable analysis, and other advanced methods should be explored. For example, it is worth investigating whether some of these techniques can be applied to selecting when to treat patients with localized prostate cancer, as posed for Research Gap 1. Shepherd et al.23 have modeled when to initiate antiretroviral treatment for individuals with HIV. The use of similar approaches to understanding when to treat localized prostate cancer might be worthwhile.
[underlined: Design:] | Statistical modeling
[underlined: Population:] | Patients with newly diagnosed, low-risk prostate cancer
[underlined: Intervention:] | Treatment or active surveillance
[underlined: Comparator:] | Different treatment choices
[underlined: Outcomes:] | Signs of disease progression, treatment among the active surveillance group.
[underlined: Setting:] | Multicenter with varying types of institutions and conditions.

The revised analytic framework, reflecting the work of the TEPP and the proposed research studies, is shown in Figure 3. The proposed projects are indicated as P1.1 for Project 1.1, etc. As shown, projects are proposed to address each of the research gaps. Furthermore, compared to the original analytic framework, shown in Figure 1, additional research gaps and projects have been identified that focus on the treatment decision.

Figure 3 Revised analytic framework for comparative effectiveness of treatments for clinically localized prostate cancer

Figure 3 (Revised analytic framework for comparative effectiveness of treatments for clinically localized prostate cancer) The figure, revised from Figure 1, depicts the key questions from the 2008 Minnesota EPC CER. Added are the research gaps and associated proposed research studies developed during the pilot project. The research gaps include identifying which patients to treat, the comparative effectiveness of treatments for clinically localized prostate cancer, and the factors which impact treatment decision-making. Research addressing the methodological challenges was also prioritized by the TEPP.