# References

1 Wilt TJ, Shamliyan T, Taylor B, et al. Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer. Comparative Effectiveness Review No. 13. (Prepared by Minnesota Evidence-based Practice Center under Contract No. 290-02-0009). Rockville, MD. Agency for Healthcare Research and Quality. February. 2008. Available at: http://www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Institute of Medicine. 2009. Initial National Priorities for Comparative Effectiveness Research. Washington, DC. The National Academies Press.
3 Schroder FH, Hugosson J, Roobol MJ, et al. Screening and prostate-cancer mortality in a randomized European study. N Engl J Med. 2009;360:1320-1328. [pmid: 19297566].
4 Andriole GL, Crawford D, Grubb RL III, et al. Mortality results from a randomized prostate-cancer screening trial. N Engl J Med. 2009;360:1310-1319. [pmid: 19297565].
5 Klotz L, Zhang L, Lam A, et al. Clinical results of long-term follow-up of a large, active surveillance cohort with localized prostate cancer. J Clin Oncol. 2009;28:126-131. [pmid: 19917860].
6 Radwan MJ, Yan Y, Luly JR, et al. Prostate-specific antigen density predicts adverse pathology and increased risk of biochemical failure. Urol. 2007;69:1121-1127. [pmid: 17572199].
7 Freedland SJ, Sun L, Kane CJ, et al. Obesity and oncological outcomes after radical prostatectomy: Impact of prostate-specific antigen-based prostate cancer screening: Results from the Shared Equal Access Regional Cancer Hospital and Duke Prostate Cancer Databases. BJUI. 2088;102:969-974.
8 Fradet V, Kurhanewicz J, Cowan JE, et al. Prostate cancer managed with active surveillance: Role of anatomic MR imaging and MR spectroscopic imaging. Radiol. 2010;256:176-183.
9 Shao Y-H, Albertsen PC, Roberts CB, et al. Less is more: Risk profiles and treatment patterns among men diagnosed as having prostate cancer and a prostate-specific antigen level below 4.0 ng/ml. Arch Intern Med. 2010;170:1256-1261. [pmid: 20660846].
10 Donnelly BJ, Saliken JC, Brasher PMA, et al. A randomized trial of external beam radiotherapy versus cryoablation in patients with localized prostate cancer. Cancer. 2010;115:4695-4704. 116. 323. 330. [pmid: 19691092].
11 Giberti C, Chiono L, Gallo F, et al. Radical retropubic prostatectomy versus brachytherapy for low-risk prostatic cancer: A prospective study. World J Urol. 2009;27:607-612. [pmid: 19455340].
12 Bill-Axelson A, Holmberg L, Filen F, et al. Radical prostatectomy versus watchful waiting in localized prostate cancer: The Scandinavian Prostate Cancer Group-4 randomized trial. J Natl Cancer Inst. 2008;100:1144-1154. [pmid: 18695132].
13 D’Amico AV, Chen MH, Renshaw AA, et al. Risk of prostate cancer recurrence in men treated with radiation alone or in conjunction with combined or less than combined androgen suppression therapy. J Clin Oncol. 2008;26:2979-2983. [pmid: 18565884].
14 Dahl DM, Barry MJ, McGovern FJ, et al. A prospective study of symptom distress and return to baseline function after open versus laparoscopic radical prostatectomy. J Urol. 2009;182:956-965. [pmid: 19616252].
15 Sanda MG, Dunn RL, Michalski J, et al. Quality of life and satisfaction with outcome among prostate-cancer survivors. N Engl J Med. 2008;358:1250-1261. [pmid: 18354103].
16 Buron C, Le Vu B, Cosset JM, et al. Brachytherapy versus prostatectomy in localized prostate cancer: Results of a French multicenter prospective medico-economic study. Int J Radiation Oncology Biol Phys. 2007;67:812-822.
17 Vickers AJ, Bianco FJ, Serio AM, et al. The surgical learning curve for prostate cancer control after radical prostatectomy. J Natl Cancer Inst. 2007;99:1171-1177. [pmid: 17652279].
18 Vickers AJ, Savage CJ, Hruza M, et al. The surgical learning curve for laparoscopic radical prostatectomy: A retrospective cohort study. Lancet Oncol. 2009;10:475-480. [pmid: 19342300].
19 Bianco FJ, Vickers AJ, Cronin AM, et al. Variations among experienced surgeons in cancer control after open radical prostatectomy. J Urol. 2010;183:977-983. [pmid: 20083278].
20 Jang TL, Bekelman JE, Liu Y, et al. Physician visits prior to treatment for clinically localized prostate cancer. Arch Intern Med. 2010;170:440-449. [pmid: 20212180].
21 Hernan MA, Lanoy E, Costagliola D, et al. Comparison of dynamic treatment regimes via inverse probability weighting. Basic Clin Pharmacol Toxicol. 2006;98:237-242. [pmid: 16611197].
22 Robins J, Orellana L, Rotnitzky A. Estimating and extrapolation of optimal treatment and testing strategies. Stat Med. 2008;27:4678-4721. [pmid: 18646286].
23 Shepherd BE, Jenkins CA, Rebeiro PF, et al. Estimating the optimal CD4 count for HIV-infected persons to start antiretroviral therapy. Epidemiology. 2010;21(5):698-705. [pmid: 20585252].