# Methods

## Identifying Recently Published and Ongoing Studies

The literature update included both (1) studies published since September 2007, the cutoff of the literature review conducted by the Minnesota EPC; and (2) clinical trials currently underway, derived from ClinicalTrials.gov. The objective was to identify major studies that might alter or inform the list of research gaps identified in the Minnesota EPC’s CER. This step was not intended to update the systematic review, which would require a broader search and more in-depth abstraction. Rather, the purpose was to identify relatively large or otherwise influential studies that might address one or more of the research gaps and, therefore, should be taken into account in identifying potential research studies. A broad scope was used to identify the pool of potential studies but a narrow set of criteria were applied to them. The TEPP was also asked to name influential articles published since the CER was released.

### Search and Yield

For published studies, a MEDLINE^®^ search was conducted using the term “prostate cancer,” limited to “clinical trial.” The search covered the period from the beginning of 2007 to July 2010. This search overlapped the time period used in the CER, because of the lag that sometimes occurs between publication of an article and its appearance in MEDLINE.^®^ Of 1,395 titles screened, 212 abstracts were reviewed. Several articles were subsequently added toward the end of the pilot project, either additional papers recommended by technical experts if they otherwise met selection criteria, or articles published while the project was underway.

The pool of potential clinical trials was drawn from a search of ClinicalTrials.gov using the search term “localized prostate cancer.” The search yielded 203 studies. Several of these studies were also mentioned by the TEPP.

### Selection Criteria

Table 2 lists the initial study selection criteria used for both published studies and ongoing clinical trials.

Table 2 Initial inclusion criteria for published studies and ongoing clinical trials

Types of | Inclusion Criteria
Studies | - RCTs; high-quality, prospective observational studies (nonrandomized comparative studies); - Active surveillance/watchful waiting arms of otherwise excluded RCTs if patients represented a setting with broad PSA testing
Populations | - Patients diagnosed with clinically localized prostate cancer; - Sample size ≥100
Interventions | Primary treatment with; - Radiotherapy (external-beam and/or brachytherapy); - Radical prostatectomy (open, laparoscopic, robotic-assisted); - Active surveillance/watchful waiting; - Androgen-deprivation therapy; - Cryotherapy; - High-intensity focused ultrasound
Outcomes | - Overall survival; - Disease-specific survival/mortality; - Biochemical, metastatic, progression-free survival; - Adverse events; - Quality of life
Multivariable analyses | Treatment interactions with; - Patient characteristics, such as age, race/ethnicity, presence or absence of comorbid illness, preferences; - Disease characteristics, such as Gleason score, tumor volume, screen versus clinically detected tumors; - Provider/hospital characteristics, such as volume and geographic region

As the research gap list was modified by the TEPP (described below), the criteria were expanded to include studies that addressed the issue of which patients to treat and other outcomes such as satisfaction with treatment decisionmaking process. The inclusion of trials on additional interventions, e.g., pharmaceutical trials, not listed above that included an active surveillance or watchful waiting arm were excluded, to keep the list of studies manageable and focus on the key studies. More generally, articles were excluded if they did not report separately on patients with T1 and/or T2 disease. Observational studies that did not take into account potential confounders, e.g., differences in treatment groups at the beginning of the study, were also omitted. Accounting for initial differences is particularly important in treatment of localized prostate cancer, because some factors, e.g., comorbidities or age, may affect both treatment selection and outcomes.

## Role and Composition of the Technical Expert and Patient Panel

The overall method proposed for this pilot project was to use a Technical Expert and Patient Panel (TEPP) to assist with the prioritization process. The intent was to elicit interdisciplinary discussion among a small group (around 9 participants) with an orientation to improving evidence in this area. This approach is primarily qualitative and builds on the BCBSA TEC EPC’s experience in leading interdisciplinary expert groups. Participation was fostered by selecting individuals with a keen interest in the issues addressed in the CER and in helping to shape future research priorities. They are national experts who are supportive of evidence-based medicine and well versed in the obstacles faced in conducting multiple, large clinical trials, especially in the context of prostate cancer. The necessary methodologic expertise included the innovative use of nonrandomized studies. This small interdisciplinary group of experts helped identify and prioritize research gaps and potential projects, taking into account which projects were feasible and potentially fundable. This pilot project can thereby help build a bridge between the synthesis of available research embodied in the CER and the conduct of future research that will target the most clinically important questions that remain to be answered.

The TEPP included practicing physicians and researchers representing an array of treatment approaches and methodologic expertise, including, for example, urology, radiation and medical oncology, family practice, biostatistics, and ethnic/population disparities. Specifically, the 11-member, multidisciplinary stakeholder Panel included two medical oncologists, a medical oncologist/hematologist, two radiation therapists, two urologists, a family practice physician, a pathologist, a biostatistician, and a consumer/patient. They came from academic medical centers, professional societies, the National Institutes of Health, and the U.S. Food and Drug Administration, but participated as individuals on the Panel, not as representatives of these organizations. Panel members were selected based on known experience, recommendations by experts, and assistance from the AHRQ Scientific Resource Center. Because of the difficulties of conducting RCTs in the field of prostate cancer, the biostatistician was selected based on his experience in using observational data in the absence of RCTs to draw causal inferences. This was not meant to exclude RCTs, but rather to widen the scope of research designs that would be considered.

This group was asked to recommend important studies published since the CER, agree upon a set of prioritization criteria, revise and prioritize the research gaps listed in the CER, and develop and prioritize a list of potential research studies to address those gaps. These tasks were accomplished through an initial one-on-one telephone call between BCBSA TEC EPC staff and each TEPP member, followed by three group conference calls as well as emails seeking feedback and prioritization. Because of difficulties in scheduling and the value of obtaining input from as many TEPP members as possible, two calls were scheduled for each of the last two conference calls. TEPP members were also asked for feedback on the pilot project itself. A process chart showing the project steps is found in Figure 2. The AHRQ Task Order Officer participated in all aspects of this pilot project. Copies of some of the interim products and means to solicit ratings or rankings can be found in Appendixes B and C.

Figure 2 Process chart for pilot project on future research on treatments for localized prostate cancer

Figure 2 (Process chart for pilot project on future research on treatments for localized prostate cancer) indicates the steps taken to involve the Technical Expert and Patient Panel (TEPP) in developing priorities and identifying research gaps, developing prioritization criteria for research studies, and ranking studies. The process includes three conference calls and distribution of minutes, summaries, and revised lists.

## Process for Establishing Future Research Priorities

### Prioritizing Research Gaps

The BCBSA TEC EPC developed prioritization criteria for use by the TEPP derived from the AHRQ criteria used for topic selection in the Effective Health Care Program (Table 3). The criteria were tailored to fit the purposes of the future research pilot and subsequently revised by TEPP members during the first conference call. The criteria “Current Importance” and “Potential for Significant Health Impact” were used to rank both research gaps and proposed studies; the criteria “Feasibility” and “Incremental Value” were also included when prioritizing the proposed research studies. The final set of criteria is shown below and was distributed to TEPP members each time they were asked to prioritize research gaps or studies. Interim version(s) are included in Appendix B.

Table 3 Prioritization criteria for research gaps and proposed research studies

Criterion | Elements
Current importance | ▪ Incorporates both clinical benefits and harms
Current importance | ▪ Represents important variation in clinical care due to controversy/uncertainty regarding appropriate care
Current importance | ▪ Addresses high costs to consumers, patients, health-care systems, or payers.
Current importance | ▪ Utility of available evidence limited by changes in practice, e.g., disease detection or evolution in technology
Potential for significant health impact | ▪ Potential for significant health impact:; ○ To improve [underlined: health outcomes]; ○ To reduce [underlined: significant variation] related to quality of care; ○ To reduce [underlined: unnecessary burden] on those with health-care problems.
Potential for significant health impact | ▪ Potential for significant economic impact, reducing unnecessary or excessive costs.
Potential for significant health impact | ▪ Potential for evidence-based change.
Potential for significant health impact | ▪ Potential risk from inaction, i.e., lack of evidence for decisionmaking produces unintended harms
Potential for significant health impact | ▪ Addresses inequities, vulnerable populations, patient subgroups with differential impact.
Incremental value (applies to proposed research studies only) | ▪ EITHER adds useful new information to existing portfolio of research on topic
Incremental value (applies to proposed research studies only) | ▪ OR addresses generalizability of existing research when body of evidence is scant
Feasibility (applies to proposed research studies only) | ▪ Interest among researchers
Feasibility (applies to proposed research studies only) | ▪ Duration
Feasibility (applies to proposed research studies only) | ▪ Cost
Feasibility (applies to proposed research studies only) | ▪ Methodologic complexity (e.g., do existing methods need to be refined?)
Feasibility (applies to proposed research studies only) | ▪ Implementation difficulty
Feasibility (applies to proposed research studies only) | ▪ Patient participation
Feasibility (applies to proposed research studies only) | ▪ Facilitating factors
Feasibility (applies to proposed research studies only) | ▪ Potential funders

During the first conference call, the TEPP members also reviewed the research gaps from the initial CER and were asked to rate them via email following the call. TEPP members were asked to rate each proposed gap for each criterion—“Current Importance” and “Potential Health Impact”—on a scale from 1 to 5, with 5 being the most important. The maximum score for a research gap per member was 10. Multiple criteria and research gaps could be assigned the same number. By the second conference call, 6 of the 10 TEPP members participating in this step had responded; the biostatistician recused himself from this process because of his relative lack of expertise regarding prostate cancer. The results for each research gap were summed across both criteria for each TEPP member and then responses for all TEPP members were added together; the gaps were then rank ordered according to the gap that was rated that highest, etc. These preliminary results were distributed to the TEPP members according to the total score assigned, and these findings were discussed during the second conference call. A final list and categorization was distributed after the second conference call and approved by TEPP members. By the end of the project, ratings had been received from 9 of the 10 TEPP members participating in this step.

### Determining Appropriate and Feasible Study Design

The TEPP generated proposed research designs. The second conference call focused primarily on brainstorming ideas for projects that might address the then-final list of research gaps. BCBSA TEC EPC staff wrote up the proposals and distributed them for more in-depth discussion during the third conference call, at which time another research gap was introduced by the TEPP (“Methodologic Challenges”). After the third conference call, BCBSA TEC EPC staff rewrote the project descriptions and included all elements of the PICOS framework.

Although TEPP members generally agreed that RCTs would be the best study design to address many of the research gaps, prior experience indicated the difficulty of conducting such trials in the United States for early stage disease. During the initial one-on-one telephone calls, several major barriers to conducting RCTs were pointed out: factors relating to the medical system culture (e.g., specialists favor their own treatment, reimbursement favors treatment over surveillance), the nature of the disease (e.g., long follow-up period), and the patient (e.g., reluctance to be randomized). Furthermore, several clinical trials are currently underway (e.g., Prostate Cancer Intervention Versus Observation Trial [PIVOT; Minneapolis VA Med Ctr; PI: Tim Wilt M.D., MPH; ISRCTN007644], Prostate Testing for Cancer and Treatment [ProtecT; Oxford Radcliffe Hospital, Great Britain; PI: Freddie C. Hamdy, M.D.; ISRCTN 20141297]), and some members advocated waiting to see what these trials reported while using alternative methodologic methods in the meantime. Therefore, the primary focus in generating a list of proposed research studies was on smaller, more limited RCTs or on other research designs.

### Prioritizing Proposed Studies for Each Research Gap

After the third conference call, TEPP members were asked to rank the proposed studies for each gap, ranging from 1 for the lowest priority to the number of studies under that gap for the highest, i.e., Gap 1 had 5 proposed studies, so the highest rank was 5. The rank was a global score that took all prioritization criteria into account; we did not request separate scores for each criterion. In this case, members were asked to take all prioritization criteria into account but were not asked to provide a separate rank for each. Responses were received from all TEPP members, and the responses for each study were summed and then ranked within each research gap.

## Engaging Stakeholders, Researchers, Funders

Stakeholders were represented indirectly through the TEPP. The members did not formally represent specific stakeholders, but they were knowledgeable about the points of view of researchers, physicians, funders, patients, and others. Through the TEPP, these views were taken into account from the beginning of the project. Members were provided with opportunities to participate by phone and via email. In some cases, members who were not able to participate in the conference calls were individually called subsequently by BCBSA TEC EPC staff to solicit their input. Additional stakeholders will have an opportunity to provide comments when AHRQ posts this document online for publication.

## Handling Conflicts of Interest

As prescribed by AHRQ, conflict of interest (COI) forms were completed by all TEPP members and staff on this project. They were reviewed initially by the project manager and delivered to AHRQ for review. There were no conflicts that were judged to preclude participation in the project. However, one potential member who initially accepted did withdraw voluntarily prior to the COI process due to a potential conflict of interest with his consulting work.

The multidisciplinary character of the TEPP and their varied stakeholder affiliations also helped to produce a balanced process. Notably, there was little discussion of specific treatment approaches or particular devices or biomarkers. Rather, the major focus of discussion was how to identify men who would benefit from treatment.