# External Inputs

The following individuals served as members of the Technical Expert and Patient Panel described in this report. Their contributions were invaluable. They have not reviewed this report and will be given the opportunity to do so when it is released publicly by AHRQ.

Peter C. Albertsen, M.D., M.S., University of Connecticut Health Center, Farmington, CT

Otis Webb Brawley, M.D., American Cancer Society, Atlanta, GA

Robert Carey, RPC Associates/Consulting Services, John’s Creek, GA

William L. Dahut, M.D., National Cancer Institute, Bethesda, MD

Barnett S. Kramer, M.D., M.P.H., National Institutes of Health, Bethesda, MD

Michael L. LeFevre, M.D., M.S.P.H., University of Missouri School of Medicine, Columbia, MO

Max Robinowitz, M.D., U.S. Food and Drug Administration, Silver Spring, MD

Chris Saigal, M.D., UCLA/RAND, Santa Monica, CA

Bryan Shepherd, Ph.D., Vanderbilt University School of Medicine, Nashville, TN

Michael J. Zelefsky, M.D., Memorial Sloan-Kettering Cancer Center, New York, NY

Anthony L. Zietman, M.D., Massachusetts General Hospital, Boston, MA