# Executive Summary

The Effective Health Care Program was initiated in 2005 to provide valid evidence about the comparative effectiveness of different medical interventions. The object is to help consumers, health care providers, and others in making informed choices among treatment alternatives. Through its comparative effectiveness reviews, the program supports systematic appraisals of existing scientific evidence regarding treatments for high-priority health conditions. It also promotes and generates new scientific evidence by identifying gaps in existing scientific evidence and supporting new research. The program puts special emphasis on translating findings into a variety of useful formats for different stakeholders, including consumers.

The full report and this summary are available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.

## Background

The objective of this project is to pilot an approach for developing future research priorities and suggesting specific projects to address evidence gaps. The topic of this pilot project, the Comparative Effectiveness of Treatments for Localized Prostate Cancer, was selected because of its importance. The project is based on a comparative effectiveness review (CER) by the Minnesota Evidence-based Practice Center (EPC).

About 1.8 million men living in the United States have a diagnosis of prostate cancer, with about 218,890 men diagnosed each year. Approximately 90 percent of men with prostate cancer have disease considered confined to the prostate gland (i.e., clinically localized disease). If left untreated, men frequently die with, rather than from, prostate cancer. Considerable overdetection and treatment may exist. However, there are no reliable ways to determine who has aggressive cancer. All treatments for prostate cancer have risks of complications, although their frequency and severity may vary.

Key questions and results from the Minnesota report are as follows:

Key Question | Summary Results
1. What are the comparative risks, benefits, short- and long-term outcomes of therapies for clinically localized prostate cancer? | - No preferred therapy; weak body of evidence.; - Differences in adverse events, convenience, costs.
2. How do specific patient characteristics, e.g., age, race/ethnicity, presence or absence of comorbid illness, preferences (e.g., tradeoff of treatment-related adverse effects vs. potential for disease progression), affect the outcomes of these therapies, overall and differentially? | - Weak evidence on impact of treatments by race/ethnicity and age.; - One randomized, controlled trial (RCT) suggested survival benefits of radical prostatectomy versus watchful waiting may be limited to men younger than 65 years.
3. How do provider/hospital characteristics affect outcomes overall and differentially (e.g., geographic region and volume)? | - Results from administrative databases and surveys suggest that provider/hospital characteristics affect outcomes.; - No information was found on volume and outcomes for brachytherapy, cryotherapy, or external beam radiotherapy.; - Higher volume surgeons tend to have fewer surgery-related complications.; - Higher volume hospitals tend to have lower surgery-related mortality, fewer late urinary complications, shorter hospital stays.; - Clinicians are more likely to recommend procedures they perform, regardless of tumor grade and prostate-specific antigen (PSA) level.
4. How do tumor characteristics, e.g., Gleason score, tumor volume, screen versus clinically detected tumors, affect the outcomes of these therapies, overall and differentially? | - Few data on comparative effectiveness of treatments by tumor characteristics.; - Estimated that PSA increases the time of detection by 5–15 years. Men with PSA-detected tumors likely to have better 20-year disease-specific survival.

The Minnesota CER concluded that more RCTs are needed to reliably assess the comparative effectiveness and adverse effects of alternative treatments. The research gaps and methodologic needs are summarized below:

Category | Research Gap
Population | - RCTs on relative effectiveness and adverse events of treatments by patient and tumor characteristics; - Nonrandomized, high quality, large prospective cohort studies or registries that identify men at diagnosis and collect patient, tumor, and treatment-decision characteristics
Interventions | - Long-term, adequately powered, randomized trials, particularly comparative trials, on emerging technologies such as intensity-modulated radiotherapy, proton beam radiation, laparoscopic and robotic-assisted prostatectomy, and cryotherapy; - A new generation of educational materials to provide balanced information for patient decisionmaking
Comparators | - Adequately powered, sufficiently long, head-to-head RCTs comparing primary treatments for localized prostate cancer; - Confirmatory trials where RCTs are available
Outcomes | - Standardized reporting of key clinically relevant outcomes; - Geographical differences in patient outcomes; - Structure and process measures for quality of care.; - Identification of factors associated with outcomes and system-wide improvement methods.
Context/other | - Approaches to adequate and timely recruitment in clinical trials; - Biomarkers to provide reliable estimates about cancer aggressiveness and relative treatment effectiveness

## Methods

The overall method proposed for this pilot project was to use a Technical Expert and Patient Panel (TEPP) to assist with the prioritization process. We recruited a group of individuals who had a keen interest in comparative effectiveness research, who were supportive of evidence-based decisionmaking, and who were well versed in the obstacles faced in conducting large clinical trials, especially in the case of prostate cancer. They were drawn from an array of clinical disciplines, including urology, radiation and medical oncology, family practice, and pathology. They also included a biostatistician specializing in innovative methodologic approaches to using observational data and a consumer participant. Although affiliated with various professional societies and other stakeholder organizations, TEPP members participated as knowledgeable individuals and not as representatives of the respective organizations with which they are affiliated.

This group was asked to recommend important studies published since the publication of the Minnesota CER, agree upon prioritization criteria, revise and prioritize the research gaps listed in the CER, and develop and prioritize a list of potential research studies to address those gaps. These tasks were accomplished through an initial one-on-one telephone call between BCBSA TEC EPC staff and each TEPP member, followed by three group conference calls and email communications.

The BCBSA TEC EPC developed prioritization criteria for use by the TEPP, derived from the Agency for Healthcare Research and Quality (AHRQ) criteria used for topic selection in the Effective Health Care Program. The criteria were tailored to fit the purposes of the future research pilot and subsequently revised by TEPP members during the first conference call. The criteria “Current Importance” and “Potential for Significant Health Impact” were used to rank both research gaps and proposed studies; the criteria “Feasibility” and “Incremental Value” were also included when prioritizing the proposed research studies. The final set of criteria was distributed to TEPP members each time they were asked to prioritize research gaps or studies.

To identify recently published and ongoing studies, an update was conducted of studies cited in MEDLINE^®^ that were published since September 2007 and of clinical trials currently underway, derived from ClinicalTrials.gov. The objective was to identify major studies that might alter or inform the research gaps identified in the Minnesota CER. This step was not intended to update the systematic review, which would require a broader search and more in-depth abstraction. Rather, the purpose was to identify important studies that addressed research gaps and should be taken into account in identifying potential research studies. A broad scope was used to identify the pool of potential studies but a narrow set of criteria were applied to them. Technical experts were also asked to name influential articles. A brief summary of the articles and trials that met search criteria was distributed to TEPP members.

Although TEPP members generally agreed that RCTs would be the best study design to address many of the research gaps, prior experience indicated the difficulty of conducting such trials in the United States for early stage disease. Furthermore, several clinical trials are currently underway; for example, the Prostate Cancer Intervention Versus Observation Trial (PIVOT) and the Prostate Testing for Cancer and Treatment (ProtecT) trial; and some members advocated waiting for results from these trials while using alternative methods in the meantime. Therefore, the primary focus in generating a list of proposed research studies was on smaller, more limited RCTs or other research designs.

Stakeholders were represented indirectly through the TEPP. The members were knowledgeable about the points of view of researchers, physicians, funders, patients, and others.

As prescribed by AHRQ, conflict of interest forms were completed by all TEPP members and staff on this project. There were no conflicts that were judged to preclude participation in the project. The multidisciplinary character of the TEPP and their varied stakeholder affiliations also helped to produce a balanced process.

## Results

Thirty recently published articles were chosen for inclusion, including two studies recommended by TEPP members. Together, these studies suggest that the benefit of PSA screening for preventing prostate cancer–related deaths may be small or nonexistent. They raise the question of overtreatment of patients with cancer detected through PSA screening. According to a 2009 study by Schroeder et al., 1,410 men would need to be screened and 48 additional subjects treated to prevent one prostate cancer death. The publication of these studies after the Minnesota EPC report may have shifted the TEPP members’ focus from “how to treat” to “whom and when to treat.”

The review of localized prostate cancer trials at ClinicalTrials.gov yielded 13 trials of potential relevance for this pilot project. The most important trials, also mentioned by several TEPP members, are the PIVOT trial in the United States, with initial results expected in about 1 year, and the ProtecT trial in the United Kingdom, with initial results expected in about 5 years. In each trial, participants were randomized to one of several treatments, including either watchful waiting or active surveillance. These trials address two of the evidence gaps selected by the TEPP. Given the time, effort, and cost required for these trials and the fact that they are already underway, TEPP members agreed that similar trials should not be initiated.

Through an iterative process, the TEPP members identified and prioritized the research gaps. They then generated and prioritized a list of potential research studies to address these gaps. The evidence gaps and specific research projects are listed in the following section. The gaps are listed in order of priority, except for Gap 4, which was not ranked. Within each gap, the proposed projects are ranked, as well.

Gap 1 Identifying Which Patients To Treat

Project 1.1. Identify predictors of disease progression
[underlined: Design:] | Prospective registry with clinical data at diagnosis and treatment, and follow up outcome data.
[underlined: Population:] | Patients with localized prostate cancer diagnosed in PSA era
[underlined: Intervention:] | Active surveillance
[underlined: Comparator:] | None (or other prostate cancer treatments)
[underlined: Outcomes:] | Timing of treatment; intermediate outcomes such as PSA failure or bone metastases; patient preferences regarding treatment throughout the period; health- related quality of life (HRQOL)
[underlined: Setting:] | Multi-institutional
Project 1.2. Standardize protocols used for patients on active surveillance
[underlined: Design:] | Prospective randomized, controlled trials or registries focusing on frequency and timing of followup, as well as timing and indications for treatment
[underlined: Population:] | Patients with localized prostate cancer in PSA era
[underlined: Intervention:] | Active surveillance
[underlined: Comparator:] | Alternative active surveillance regimens
[underlined: Outcomes:] | Disease progression, time to treatment, treatment outcomes, quality of life, patient preferences
[underlined: Setting:] | Multi-institutional
Project 1.3a. Facilitate future research on potential biomarkers to identity patients whose disease is likely to be aggressive
[underlined: Design:] | Establish biospecimen repositories with clinical data on diagnosis, treatment, and followup
[underlined: Population:] | Patients with localized prostate cancer diagnosed in PSA era
[underlined: Intervention:] | Collecting tumor, serum, and urine specimens; and clinical data
[underlined: Comparator:] | None
[underlined: Outcomes:] | Time to progression, disease-specific and overall survival
[underlined: Setting:] | Prospective studies of localized prostate cancer
Project 1.3b. Evaluate whether all patients with elevated PSA scores warrant immediate biopsy
[underlined: Design:] | RCT
[underlined: Population:] | Patients with elevated PSA scores on screening
[underlined: Intervention:] | Immediate biopsy
[underlined: Comparator:] | Delayed biopsy performed based on PSA velocity. Might also vary PSA cutpoints.
[underlined: Outcomes:] | Cancer detection, disease progression, patient preferences
[underlined: Setting:] | Multi-institutional
Project 1.5. Investigate more accurate and reliable methods of identifying grade of disease after biopsy
[underlined: Design:] | Observational or specimens from prior RCTs
[underlined: Population:] | Patients undergoing biopsy for possible prostate cancer
[underlined: Intervention:] | Alternative metrics for diagnosing prostate cancer, with objective criteria to standardize pathology interpretations, and testing biomarkers that may predict disease progression
[underlined: Comparator:] | Current methods for diagnosing prostate cancer
[underlined: Outcomes:] | Inter-rater and inter-institutional reliability, disease progression, treatment outcomes (progression-free survival [PFS], overall survival [OS])
[underlined: Setting:] | Multi-institutional

Gap 2 Comparative Effectiveness of Different Treatment for Localized Prostate Cancer

Project 2.1. Comparative effectiveness of alternative treatments within a modality
[underlined: Design:] | RCT
[underlined: Population:] | Patients with recently diagnosed localized prostate cancer
[underlined: Intervention:] | Treatments for prostate cancer
[underlined: Comparator:] | Alternative treatments within a modality such as surgery (e.g., robotic-assisted laparoscopic prostatectomy vs. open radical prostatectomy) or radiation therapy (e.g., intensity-modulated vs. proton beam therapy)
[underlined: Outcomes:] | Adverse events, HRQOL over 5–8 years, time to recurrence, cost-effectiveness
[underlined: Setting:] | Multi-institutional. Include facilities and physicians with different characteristics.
Project 2.2a. Evaluate frequency of use of androgen-deprivation therapy (ADT) for low-risk prostate cancer
[underlined: Design:] | Physician survey or analysis of combined registry and claims data. This could also be developed as an RCT of ADT vs. delayed ADT.
[underlined: Population:] | Patients with low-risk, localized prostate cancer
[underlined: Intervention:] | ADT
[underlined: Comparator:] | No use of ADT
[underlined: Outcomes:] | Frequency of ADT, outcomes of ADT
[underlined: Setting:] | Multi-institutional. Include facilities and physicians with different characteristics.
Project 2.2b. Long-term sequelae of treatments for localized prostate cancer
[underlined: Design:] | Longitudinal, cohort study
[underlined: Population:] | Patients treated for low-risk, localized prostate cancer
[underlined: Intervention:] | Any treatment for localized prostate cancer
[underlined: Comparator:] | Other treatments for prostate cancer or active surveillance
[underlined: Outcomes:] | Adverse events such as urinary and fecal incontinence, erectile dysfunction, unrelated cancer
[underlined: Setting:] | Multi-institutional. Include facilities and physicians with different characteristics.

Gap 3 Factors with an Impact on Treatment Decisionmaking

Project 3.1. Evaluate patient preferences and perceptions of risk in selecting prostate cancer treatment
[underlined: Design:] | Survey pre- and post-treatment
[underlined: Population:] | Patients with recently diagnosed localized prostate cancer
[underlined: Intervention:] | Any treatment for localized prostate cancer and active surveillance
[underlined: Comparator:] | Alternative treatment or active surveillance
[underlined: Outcomes:] | Patients’ preferences, perceptions of risk, and treatment choices, pre- and post- treatment
[underlined: Setting:] | Multicenter with different types of institutions and physicians
Project 3.2. Increasing use of shared decisionmaking by physicians and patients
[underlined: Design:] | Compare different approaches to incorporating decision aids and shared decisionmaking into clinical practice.
[underlined: Population:] | Clinics treating patients with recently diagnosed localized prostate cancer
[underlined: Intervention:] | To be defined
[underlined: Comparator:] | To be defined
[underlined: Outcomes:] | Use of decision aids, impact on treatment choices, factors that facilitate or serve as barriers to adoption of these tools
[underlined: Setting:] | Multicenter with different types of institutions
Project 3.3. Study the psychological impact of diagnosis and treatment, especially for those under active surveillance.
[underlined: Design:] | Survey pre- and post-treatment (length of followup to be specified)
[underlined: Population:] | Patients with recently diagnosed localized prostate cancer undergoing treatment or in active surveillance
[underlined: Intervention:] | Any treatment for localized prostate cancer and active surveillance
[underlined: Comparison:] | Across treatments and active surveillance
[underlined: Outcomes:] | Measures of psychological well-being
[underlined: Setting:] | Multicenter with different types of institutions

Gap 4 Methodologic Challenges

Project 4.1. Exploring methods to increase patient adherence with randomization scheme
[underlined: Design:] | Surveys to help understand participants’ decisionmaking; measuring the effectiveness of approaches intended to reduce unplanned crossing over to another arm
[underlined: Population:] | Patients with newly diagnosed, low-risk prostate cancer
[underlined: Intervention:] | To be defined
[underlined: Comparator:] | No intervention
[underlined: Outcomes:] | Nonadherence with randomization assignment
[underlined: Setting:] | Multicenter with varying types of institutions and conditions
Project 4.2 . Increasing the use of statistical modeling and other advanced methods in studies on localized prostate cancer
[underlined: Design:] | Statistical modeling
[underlined: Population:] | Patients with newly diagnosed, low-risk prostate cancer
[underlined: Intervention:] | Treatment or active surveillance
[underlined: Comparator:] | Different treatment choices
[underlined: Outcomes:] | Signs of disease progression, treatment among the active surveillance group
Setting: | Multicenter with varying types of institutions and conditions

## Conclusions

The treatment of localized prostate cancer is a high priority issue due to the prevalence of disease, concern about potential overtreatment with accompanying adverse events, and the potential for severe disease and death for a small portion of patients. An overriding concern, however, is the weakness of the current state of evidence to guide individual patient decisionmaking. Because of the well recognized difficulties in maintaining robust, long-term RCTs on localized prostate cancer in the United States, the core of our approach to this pilot project was to convene an interdisciplinary TEPP. Our experience in the pilot project was that the TEPP members meshed to provide new insights into prioritizing research gaps and a diversity of approaches to the proposed research studies to address these gaps. Most notably, the TEPP reframed the most important underlying research question in the field. While most prior formulations had focused on comparing treatment strategies, the Panel concurred that the critical question is how to identify the patients with newly diagnosed, localized prostate cancer who would benefit from early treatment. Racial and ethnic disparities in treatments and outcomes were recognized as important, but again, it is difficult to address this issue without knowing more about which patients should be treated and which treatments will work best for them.

While acknowledging the RCT as the ideal study design, the TEPP recognized the need for alternative methodologies to address both questions of who should be treated and questions of the comparative effectiveness of treatments. To address the question of who should be treated, the Panel envisioned the use of prospective registries of patients under active surveillance. Linked to this would be a biospecimen repository that would permit future analyses of novel biomarkers. The TEPP also identified “meta-gaps,” methodologic challenges generalizable to diseases and settings beyond localized prostate cancer. For RCTs, the Panel endorsed the need to explore methods to increase patient adherence with randomization schemes, because unplanned crossover confounds interpretation of trial results. The Panel also supported advancing the use of statistical modeling, instrumental variable analysis, and other advanced methods that might replicate some of the strengths of an RCT but use observational data, which is often more feasible to obtain than launching a de novo RCT.

We offer some lessons learned from the pilot project that would be useful to apply to ongoing efforts to develop future research needs white papers prepared in conjunction with comparative effectiveness reviews:

- Convening teleconferences was an effective way of leveraging the synergies of an interdisciplinary group and enjoyable for the participants.
- Although we used a process of rank-ordering the research study priorities, we found the qualitative discussions more informative.
- In our experience, the process of quantitative rank ordering of priorities did generally not distinguish sufficiently among options.
- We recommend an AHRQ EPC methods project that will review the literature on eliciting preferences and make recommendations for the application of such methodologies to future research needs projects conducted in conjunction with comparative effectiveness reviews.
- The pilot process was successful for prioritizing research gaps and identifying, at a high level, projects that would address those gaps. However, the scope of the pilot project was such that potential research studies could only be sketched out at a very general level.
- To achieve a greater richness in the thinking about potential research studies, we recommend generating ideas for such studies only for the highest priority evidence gap.