# Discussion

The treatment of localized prostate cancer is a high-priority issue due to the prevalence of disease, concern about potential overtreatment with accompanying adverse events, and the potential for severe disease and death for a small portion of patients. An overriding concern, however, is the weakness of the current state of evidence to guide individual patient decisionmaking. The difficulties of conducting research on treatments for localized prostate cancer include inconsistencies in diagnosis and disease staging; strong views among both patients and treating physicians about the best course of treatment; and the long course of the disease for most patients, making outcomes of the disease and treatment difficult to evaluate.

Because of the well-recognized difficulties in maintaining robust, long-term randomized controlled trials on localized prostate cancer in the United States, the core of our approach to this pilot project was to convene an interdisciplinary Technical Expert and Patient Panel (TEPP). We recruited a group of individuals who had a keen interest in comparative effectiveness research; who were supportive of evidence-based decisionmaking; and who were well-versed in the obstacles faced in conducting large clinical trials, especially in the case of prostate cancer. The Panelists were drawn from an array of clinical disciplines, including urology, radiation and medical oncology, family practice, pathology, and also including a biostatistician specializing in innovative approaches to using observational data and a consumer participant. Although affiliated with various professional societies and other stakeholder organizations, Panel members participated as knowledgeable individuals and not as representatives of the respective organizations with which they were affiliated. Our experience in the pilot project was that the TEPP members meshed to provide new insights into prioritizing research gaps and a diversity of approaches to the proposed research studies to address these gaps.

Most notably, the TEPP reframed the most important underlying research question in the field. While most prior formulations had focused on comparing treatment strategies, the Panel concurred that the critical question is how to identify the patients with newly diagnosed, localized prostate cancer who would benefit from early treatment. And upon reflection, this is indeed the a priori question. To assess the comparative effectiveness of treatments, the prerequisite should be to compare them in a population that is likely to have more aggressive disease and therefore benefit from early treatment. Racial and ethnic disparities in treatments and outcomes were acknowledged as important, but again, it is difficult to address this issue without knowing more about which patients should be treated and which treatments will work best for them.

In his comments on this project, one of the TEPP members summarized the challenges well:

Many men will die “with prostate cancer” but not “from prostate cancer” and will never have any cancer related symptoms. Since all treatments have side effects — with some being quite significant — the potential for overtreatment is a real problem in this disease. Nevertheless about 32,000 men die yearly from this disease, while many others have cancer related pain. Thus, the single biggest challenge for researchers is to identify a means to distinguish lethal from nonlethal prostate cancer. Without this information we are likely to undertreat or overtreat our patients. Even within these broad categories, prostate tumors may have very different characteristics which may ultimately guide treatment decisions. Not all prostate tumors are like other prostate tumors, and they do not all respond to therapy in the same ways.

It is unfortunate that as we attempt to “crack the code” of lethal prostate cancer we are left with biospecimens and cancer registries as our tools. The current state of the science is not quite ready for prospective randomized trials of genetic/molecular markers of potential prostate cancer lethality. However, ultimately, that is what will be needed to make a meaningful difference.

Also notable, the TEPP, while acknowledging the RCT as the ideal, recognized the need for alternative methodologies to address both questions of who should be treated and questions of the comparative effectiveness of treatments. The TEPP members held a range of views on what can be accomplished outside of clinical trials, and the final list of studies contains a mix of research designs. The TEPP envisioned the use of prospective registries of patients under active surveillance with detailed clinical data at diagnosis, treatment and follow-up. Linked to this would be a biospecimen repository that would permit future analyses of novel biomarkers. A corollary is to standardize protocols used for patients on active surveillance, a step that would yield more robust data and enable aggregation across a number of studies or sites.

The TEPP highlighted two important and large RCTs that are presently underway: the PIVOT trial in the United States, with initial results expected in about one year, and the ProtecT trial in the United Kingdom, with initial results expected in about five years. In each trial, participants were randomized to one of several treatments, including either watchful waiting or active surveillance. In the ProtecT trial, enrollees were initially randomized to PSA screening and then those in whom prostate cancer was detected were randomized to treatment. Given the time, effort, and cost required for these trials and the fact that they are already underway, TEPP members agreed that similar trials should not be initiated.

Ultimately, a major focus was put on methodologic issues, both for RCTs and observational studies. The TEPP added to the additional list of evidence gaps in localized prostate cancer a “meta-gap” on methodologic challenges, a gap generalizable to diseases and settings beyond localized prostate cancer. Noting that some RCTs have been difficult to interpret because of unplanned crossover of patients from one arm to another, the TEPP endorsed the need to explore methods to increase patient adherence with randomization schemes of RCTs. And because it is often difficult to conduct RCTs on the major questions of interest, because of their cost and complexity, the Panel also supported advancing the application of statistical modeling, instrumental variable analysis, and other advanced methods that might replicate some of the strengths of a randomized controlled trial, but use observational data.

Finally, we offer some observations on the pilot project. Our observations incorporate perspectives from both the EPC and from members of the TEPP. First, convening teleconferences was an effective way of leveraging the synergies of an interdisciplinary group, and the Panelists enjoyed participating in these discussions. As a practical matter, however, it was not always possible to schedule the entire group in a single conference call. Most of the teleconferences had to be held in two sessions, with about half of the participants on each call. This was a workable arrangement, but less desirable than convening the entire group.

Second, while we used a process of rank-ordering the research study priorities, in many respects we found the qualitative discussions more informative. It would be helpful in the future to get a deeper understanding of the methodologies available to elicit preferences, especially in small groups. On the other hand, the clustering of results might also reflect the diversity of views within the Panel. The members generally agreed on the highest priority, but beyond that, they held diverse views and no prevailing consensus emerged around other priorities.

Third, we found that it was easier to apply the process to prioritize research gaps and identify at a high level projects that would address those gaps. However, we could only sketch out the potential research studies at a very general level. Fleshing out research studies takes considerable time and effort. Within the scope of the pilot project, and likely subsequent future research needs projects, the approach to describing studies must necessarily be general. As one member noted, the best way to get good proposals to fill specific gaps may be to issue a request for proposals (RFP). Indeed, it was the EPC’s expectations prior to the pilot project that we would be able to delineate proposed research studies with sufficient detail to support another organization in developing an RFP. However, we do not think that specification of the core elements pertinent to an RFP could be achieved within the scope of the pilot project.

Fourth, a limitation that was an artifact of the pilot project is that two years had elapsed between the completion of the comparative effectiveness review and the start of the future needs project. Thus, the evidence base had evolved since the original formulation of future research needs.