# Conclusions

The treatment of localized prostate cancer is a high-priority issue due to the prevalence of disease, concern about potential overtreatment with accompanying adverse events, and the potential for severe disease and death for a small portion of patients. An overriding concern, however, is the weakness of the current state of evidence to guide individual patient decisionmaking. Because of the well-recognized difficulties in maintaining robust, long-term RCTs on localized prostate cancer in the United States, the core of our approach to this pilot project was to convene an interdisciplinary TEPP. Our experience in the pilot project was that the TEPP members meshed to provide new insights into prioritizing research gaps and a diversity of approaches to the proposed research studies to address these gaps. Most notably, the TEPP reframed the most important underlying research question in the field. While most prior formulations had focused on comparing treatment strategies, the Panel concurred that the critical question is how to identify the patients with newly diagnosed, localized prostate cancer who would benefit from early treatment. Racial and ethnic disparities in treatments and outcomes were recognized as important, but again, it is difficult to address this issue without knowing more about which patients should be treated and which treatments will work best for them. While acknowledging the RCT as the ideal, the TEPP recognized the need for alternative methodologies to address both questions of who should be treated and questions of the comparative effectiveness of treatments.

To address who should be treated, the Panel envisioned the use of prospective registries of patients under active surveillance. Linked to this would be a biospecimen repository that would permit future analyses of novel biomarkers. The TEPP also identified “meta-gaps,” methodologic challenges generalizable to diseases and settings beyond localized prostate cancer. For RCTs, the Panel endorsed the need to explore methods to increase patient adherence with randomization schemes, because unplanned crossover confounds interpretation of trial results. The Panel also supported advancing the use of statistical modeling, instrumental variable analysis, and other advanced methods that might replicate some of the strengths of a randomized controlled trial, but use observational data, which is often more feasible to obtain than launching a de novo RCT.

We offer some lessons learned from the pilot project that would be useful to apply to ongoing efforts to develop future research needs white papers prepared in conjunction with comparative effectiveness reviews.

- Convening teleconferences was an effective way of leveraging the synergies of an interdisciplinary group and enjoyable for the participants.
- Although we used a process of rank-ordering the research study priorities, we found the qualitative discussions more informative.
- In our experience, the process of quantitative rank ordering of priorities did generally not distinguish sufficiently among options.
- We recommend an AHRQ EPC methods project that will review the literature on eliciting preferences, and make recommendations for the application of such methodologies to future research needs projects conducted in conjunction with comparative effectiveness reviews.
- The pilot process was successful for prioritizing research gaps and identifying, at a high level, projects that would address those gaps. But the scope of the pilot project was such that potential research studies could only be sketched out at a very general level.
- To achieve a greater richness in the thinking about potential research studies, we recommend generating ideas for such studies only for the highest priority evidence gap.