# Background

## Burden of Illness^a^ a The text of this section and the following section on “2008 Comparative Effectiveness Review” is largely drawn from the 2008 Minnesota EPC CER. The findings for each key question are reproduced verbatim, although some paragraphs were omitted in the interest of brevity. The full text is available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.

An estimated 1.8 million men living in the United States have a diagnosis of prostate cancer, with about 218,890 newly diagnosed men each year. Approximately 90 percent of men with prostate cancer have disease considered confined to the prostate gland (i.e., clinically localized disease). If left untreated, frequently men die with, rather than from, prostate cancer. Largely because of widespread prostate-specific antigen (PSA) testing, the lifetime risk of prostate cancer diagnosis in the United States has nearly doubled to 20 percent, while the risk of dying of prostate cancer has remained at approximately 3 percent. Therefore, considerable overdetection and treatment may exist. Moreover, the treatment of localized prostate cancer is associated with substantial adverse effects.

The primary goal of treatment is to target those men most likely to need intervention to prevent prostate cancer death and disability, while minimizing intervention-related complications. Common treatments include watchful waiting (active surveillance), surgery to remove the prostate gland (i.e., radical prostatectomy), radiotherapy (e.g., external-beam radiation or brachytherapy), freezing the prostate (i.e., cryotherapy), and androgen-deprivation therapy (ADT). All treatments for prostate cancer have risks of complications, although their frequency and severity may vary. Common adverse events include urinary, bowel, and sexual dysfunction. The vast majority of prostate cancers currently detected in the United States are asymptomatic, clinically localized, and found on routine PSA testing. PSA testing detects more tumors, at an earlier stage, with a smaller volume within each stage, and at an earlier period in a man’s life than nonscreen-detected tumors. The clinical significance, natural history, and comparative effectiveness of treatments in PSA-detected cancers are not known but likely differ from those detected and treated in the pre-PSA era (before the late 1980s to early 1990s).

## 2008 Comparative Effectiveness Review

The Minnesota EPC’s comparative effectiveness review (CER) on Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer1 covered studies published between 2000 and September 2007. The key questions addressed in the report are listed below:

- Key Question 1. What are the comparative risks, benefits, short- and long-term outcomes of therapies for clinically localized prostate cancer?
- Key Question 2. How do specific patient characteristics, e.g., age, race/ethnicity, presence or absence of comorbid illness, preferences (e.g., tradeoff of treatment-related adverse effects vs. potential for disease progression), affect the outcomes of these therapies, overall and differentially?
- Key Question 3: How do provider/hospital characteristics affect outcomes overall and differentially (e.g., geographic region and volume)?
- Key Question 4: How do tumor characteristics, e.g., Gleason score, tumor volume, screen vs. clinically detected tumors, affect the outcomes of these therapies, overall and differentially?

An abbreviated version of the major findings reported in the Minnesota EPC’s report follows:

### Key Question 1 What are the comparative risks, benefits, and outcomes of therapies?

No one therapy can be considered the preferred treatment for localized prostate cancer due to limitations in the body of evidence as well as the likely tradeoffs an individual patient must make between estimated treatment effectiveness, necessity, and adverse effects. All treatment options result in adverse effects (primarily urinary, bowel, and sexual), although the severity and frequency may vary between treatments. Even if differences in therapeutic effectiveness exist, differences in adverse effects, convenience, and costs are likely to be important factors in individual patient decisionmaking. Patient satisfaction with therapy is high and associated with several clinically relevant outcome measures. Data from nonrandomized trials are inadequate to reliably assess comparative effectiveness and adverse effects. Additional randomized controlled trials (RCTs) are needed….

### Key Question 2 How do patient characteristics affect outcomes?

No RCTs reported head-to-head comparisons of treatment outcomes stratified by race/ethnicity, and most did not provide baseline racial characteristics. Available data were largely from case series. Few studies reported head-to-head comparisons, and there was limited adjustment for confounding factors. Modest treatment differences reported in some nonrandomized studies have not been consistently reported in well-powered studies. There was little evidence of a differential effect of treatments based on age. While differences exist in the incidence and morbidity of prostate cancer based on patient age and there are differences in the treatments offered to men at different age ranges, few studies directly compared the treatment effects of different therapies across age groups. Most RCTs did not have age exclusion criteria. The mean/median age ranged from a low of 63 years for trials of radical prostatectomy to 72 years for trials of external beam radiotherapy. Only one RCT provided subgroup analysis according to age. Results suggest that survival benefits of radical prostatectomy compared with watchful waiting may be limited to men less than 65 years of age. Practice patterns from observational studies show that radical prostatectomy is the most common treatment option in younger men with localized prostate cancer.

### Key Question 3 How do provider and hospital characteristics affect outcomes?

Results from national administrative databases and surveys suggested that provider/hospital characteristics, including radical prostatectomy procedure volume, physician specialty, and geographic region, affect outcomes. (There was no information on volume and outcomes for brachytherapy, cryotherapy, or external beam radiotherapy.) Patient outcomes varied in different locations and were associated with provider and hospital volume independent of patient and disease characteristics. Screening practices can influence the characteristics of patients diagnosed and tumors detected. Screening practices and treatment choices varied by physician specialty and across regions of the United States. These did not correlate with clinician availability. Clinicians were more likely to recommend procedures they performed regardless of tumor grades and PSA levels….

### Key Question 4 How do tumor characteristics affect outcomes?

Few data existed on the comparative effectiveness of treatments based on PSA levels, histologic score, and tumor volume to identify low-, intermediate-, and high-risk tumors. We [the Minnesota EPC] focused on baseline PSA levels and Gleason histologic score. The natural history of PSA-detected tumors is not known because few men remain untreated for a long period. One report assessed 20-year outcomes in the United States from a cohort of 767 men with prostate cancer detected prior to PSA testing and treated with watchful waiting. Histologic grade was associated with overall and prostate-cancer-specific survival. Men with low-grade prostate cancers had a minimal risk of dying from prostate cancer (7 percent with Gleason score 2–4 died due to prostate cancer). Men with high-grade prostate cancers had a high probability of dying from their disease within 10 years of diagnosis, regardless of their age at diagnosis (53 percent with Gleason score 8–10 died due to prostate cancer). Estimates from large ongoing screening trials suggest that PSA increases the time of detection by 5–15 years. Therefore, it is likely that men with PSA-detected tumors will have better 20-year disease-specific survival than this cohort….

## Research Gaps

As presented in the original CER of the Minnesota EPC, the research gaps combined both the topics with insufficient evidence and the types of studies needed to address them. The CER noted the following limitations in the existing evidence for Key Question 1:

- Few randomized trials directly compared the relative effectiveness between (rather than within) major treatment categories.
- Many randomized trials are inadequately powered to provide long-term survival outcomes, with the majority reporting biochemical progression or recurrence as the main outcomes.
- Some randomized trials were old, conducted prior to prostate cancer detection with PSA testing … and used technical aspects of treatment that may not reflect current practice; therefore, their results may not be generalizable to modern practice settings.
- Wide variation existed in reporting and definitions of outcomes.
- There was little reporting of outcomes according to major patient and tumor characteristics.
- Emerging technologies have not been evaluated in randomized trials.

The analytical framework for the original CER prepared by BCBSA TEC is as follows:

Figure 1 Analytic framework for comparative effectiveness of treatments for clinically localized prostate cancer

Figure 1 (Analytic framework for comparative effectiveness of treatments for clinically localized prostate cancer) is a flowchart that shows the key questions from the 2008 Minnesota EPC Comparative Effectiveness Review (CER). Patients with clinically localized prostate cancer select a treatment, which may have adverse events associated with it. Intermediate outcomes include biochemical response and progression. The final health outcomes are mortality/survival and quality of life. The research gaps are also noted on the figure and the corresponding text on page 5 explains that “the current research gaps identified in the CER relate to the relative lack of head-to-head comparisons of the various treatment options, their impact on both outcomes and adverse events, and the differences for various populations (e.g. age and ethnicity or disease characteristics) and types of providers.

The patients of interest have clinically localized prostate cancer. They undergo treatment, including the possibility of watchful waiting or delaying treatment, surgery, radiotherapy, or another approach. There are adverse events associated with these treatments, including most commonly urinary, bowel, and sexual effects. The outcomes measured may include intermediate outcomes, such as biochemical response or disease progression, or final health outcomes such as overall survival or long-term quality of life. The current research gaps identified in the CER relate to the relative lack of head-to-head comparisons of the various treatment options, their impact on both outcomes and adverse events, and the differences for various populations (e.g., age and ethnicity or disease characteristics) and types of providers.

The research gaps identified in the Minnesota EPC’s CER were organized by the BCBSA TEC EPC into PICOS categories (i.e., population, intervention, comparators, outcomes, settings) as arrayed in Table 1. To summarize briefly, the evidence base amassed and evaluated by the Minnesota EPC provided insufficient evidence to address definitively any of the Key Questions regarding this important clinical issue.

Table 1 Research gaps identified in Minnesota EPC CER, as selected and categorized by the BCBSA TEC EPC

Category | Research Gap
Population | - RCTs that address relative effectiveness and adverse events of all treatments by patient characteristics (race/ethnicity, age, comorbidity) and tumor characteristics (PSA, stage, histologic grade).; - Use of nonrandomized, high-quality, large prospective cohort studies or cancer registries that identify men at the time of diagnosis and collect comprehensive patient, tumor, and treatment-decision characteristics. Should report or provide data for head-to-head comparisons, adjustment for confounding factors, and use of standardized definitions.
Intervention | - Long-term, adequately powered randomized trials, particularly comparative trials, are needed on emerging technologies such as intensity-modulated radiotherapy (IMRT), proton beam radiation, laparoscopic and robotic- assisted prostatectomy, and cryotherapy; - Develop new generation of educational materials to provide balanced information about the risks and benefits of treatments and assist in patient decisionmaking and incorporation of patient-centric values.
Comparator | - Adequately powered, sufficiently long, head-to-head RCTs comparing primary treatments for localized prostate cancer, especially watchful waiting, radical prostatectomy, external beam radiation therapy, brachytherapy, and androgen deprivation therapy.; - Confirmatory trials where RCTs available.
Outcomes | - Standardized reporting of key clinically relevant outcomes, including overall, disease-specific, and metastatic-free survival; biochemical non-evidence of disease (bNED); adverse effects; and disease-specific quality of life/health status.; - Clarify geographical differences in patient outcomes by evaluating nationally representative databases using appropriate risk adjustment.; - Develop structure and process measures associated with quality of prostate cancer care. Identify factors associated with various outcomes and develop system-wide improvement methods.
Setting/other | - Investigate approaches to ensure adequate and timely recruitment in clinical trials.; - Identify biomarkers to provide reliable estimates about prostate cancer aggressiveness and the relative effectiveness of treatments.

Underlying the current importance of this topic are the prevalence of disease, the concern about potential overtreatment with accompanying adverse events, and the risk of severe disease and death for a small proportion of patients with localized disease. Another contributing factor, however, is the weakness of the current state of evidence. This is due in part to the difficulties in conducting research on treatment for localized prostate cancer, which is challenging for a variety of reasons, including:

- inconsistencies in diagnosis and disease staging (for example, the same biopsy specimen may now be assigned a higher Gleason score than it would have in the past);
- the strong views among both prostate cancer patients and many treating physicians about the best course of treatment (and therefore a reluctance to participate in randomization);
- the long course of the disease, which of course benefits patients but requires long follow-up for studies;
- the fact that selection of treatment is often influenced by prostate-cancer-specific or other risk factors, which makes observational studies more difficult;
- the distinct profiles of adverse events associated with each treatment; and
- the relatively recent adoption of widespread PSA screening in the United States, relative to the average survival for those diagnosed early through PSA testing, leaving many studies of treatment effects or surveillance without sufficient follow-up to gauge the comparative effectiveness over the whole course of the disease.