# Appendixes

Appendix A List of Recently Published and Ongoing Studies

Appendix B Prioritization Tools

Appendix C Interim List of Potential Research Studies