# Interim List of Potential Research Studies

This appendix contains the first draft of the list of proposed research studies (July 9, 2010). This list was composed by BCBSA TEC EPC staff based on discussions during the second TEPP conference call. It was distributed to the TEPP for comment and review before the third conference call.

## Projects to Address Gap 1: Identifying which patients to treat

[underlined: Project 1.1]. Multi-institutional, observational study/registry to identify predictors of disease progression. Collect all relevant data on patients selecting active surveillance (AS), including tissue, serum, and urine; other risk factors (e.g., perineural invasion, inflammation); reasons for selecting AS; comorbidities; quality of life (QOL); etc. Although survival would take many years to gauge, potential intermediate outcomes include bone metastases and PSA failure. An “Oncotype Dx” type study could then be performed. Might also issue RFP asking for ideas on how analyze such data.

[underlined: Project 1.2]. More generally, establishing banks of tumor, serum, and urine that can be used in future studies of biomarkers. (As a reminder one member mentioned that a large bank has been created as part of PROTECT trial).

[underlined: Project 1.3]. Triage study of response to suspicious PSA results on screening, similar to studies done for cervical cancer: biopsy now, delay biopsy, etc. Could also address variations in the ways in which PSA is interpreted, e.g., cutpoints.

[underlined: Project 1.4]. Identify grade of disease after biopsy, using more biomarkers.

[underlined: Project 1.5]. Use modeling to determine when to begin treatment, similar to research done on HIV-positive patients.

## Projects to Address Gap 2: Comparative effectiveness of different treatments for localized prostate cancer

[underlined: Project 2.1]. Multicenter RCTs of alternative treatments within a modality, with focus on adverse events and QOL within a relatively short time frame, e.g., 5 years. Could address the value added by more expensive technologies. Also, need to include different types of facilities (e.g., academic medical centers and community hospitals) and physicians with varying experience and training.

[underlined: Project 2.2]. Evaluate frequency of use of ADT in men with low risk prostate cancer, given serious side effects, including cardiac disease. When and for whom do the benefits outweigh the adverse events?

[underlined: Project 2.3]. Study the psychological impact of diagnosis and treatment, especially for those under active surveillance.

## Projects to Address Gap 3: Factors with impact on treatment decisionmaking

[underlined: Project 3.1]. Evaluate patient preferences and perceptions of risk in weighing adverse effects of treatment vs. chance for benefit.