# Prioritization Tools

This appendix contains a series of materials created by BCBS EPC and used by the TEPP in identifying prioritization criteria; ranking research gaps, with preliminary results; and requesting ranking of the draft list of proposed research studies. Items II-VI stem from the TEPP conference calls. In each case, the final results are presented in the report.

I. Prioritization Criteria, 1st Draft, May 14, 2009 (distributed to TEPP before first conference call)

II. Prioritization criteria, 2nd Draft, May 19, 2009 (distributed to TEPP after first conference call)

III. Tool Used To Solicit TEPP Members’ Research Gap Ratings via Email (May 19, 2010) (distributed to TEPP after first conference call, with item II above)

IV. Results from Research Gap Rating Tool

V. Second List of Prioritized Research Gaps (July 9, 2010) (distributed to TEPP before second conference call)

VI. Tool Used To Solicit TEPP Members’ Proposed Study Ratings via Email and Final Comments on Research Gap List(July 26, 2010) (distributed to TEPP after third conference call)