# List of Recently Published and Ongoing Studies

Table A-1 Recently published studies

Research Gap | Study | Study objective | Research design | Sample size; Years; Location; Follow-up | Treatment(s) | Outcomes | Summary results
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | Shappley WV, Kenfield SA, Kasperzyk et al. Prospective determinants and outcomes of deferred treatment or watchful waiting among men with prostate cancer in a nationwide cohort. J Clin Oncol 2009; 27:4980–5. | To examine the consequences of deferred treatment as initial management in a contemporary prospective cohort of American men with prostate cancer. | Prospective study based on the Health Professional Follow-up Study | 342 (of 3331 followed with prostate cancer) Subjects initially enrolled in 1986 FU: mean = 8.3 yrs (SD=4.6) | Deferred treatment or watchful waiting | Time to initiation of active treatment, time to metastasis or death due to prostate cancer | 51% remained untreated throughout follow up (mean=7.7 yrs); remainder treated an average of 3.9 yrs after diagnosis. Factors associated with progression to treatment included younger age, higher clinical stage, higher Gleason score, and higher PSA at diagnosis. Rates of metastasis and death from prostate cancer were similar between those who chose immediate treatment and those who deferred it. Of those who deferred treatment, 63.2% were stage T1; 34.1%, T2; 2.3%, T3; 0.3%, N1/M1. About 75% had a Gleason score < 6.
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | Andriole GL, Crawford D, Grubb RL III et al. Mortality results from a randomized prostate-cancer screening trial. N Engl J Med 2009; 360:1310–9. | To determine the effect of annual PSA testing and digital rectal examination (DRE) on mortality from prostate cancer. | RCT | 76,693 1993–2001 Multicenter in US FU: median = 11.5 yrs | Screening (PSA and DRE) versus usual care | Cause-specific mortality, cancer incidence, staging, and survival | Few deaths from prostate cancer at 7–10 yrs and no significant difference between study groups (rate ratio = 1.13; 95% CI: 0.75, 1.70). Majority prostate cancers were stage 2 at diagnosis with Gleason score of 5–6. Compliance with screening was about 85% in the intervention group (annual PSA for 6 years; DRE for 4 yrs). In the control group, PSA testing increased from 40% in year 1 to 52% in year 6; and ranged from 41% to 46% for DRE.
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | Schroder FH, Hugosson J, Roobol MJ et al. Screening and prostate-cancer mortality in a randomized European study. N Engl J Med 2009; 360:1320–8. | To evaluate the effect of screening with PSA on death rates from prostate cancer. | RCT; but protocols differed by country, e.g., PSA cutoff value. In some countries, patients knew assignments before agreeing to participate and were more compliant with screening. | 162,387 Multicenter Europe FU: median = 9 yrs | PSA screening (~once every 4 yrs) or not | Overall and prostate cancer mortality. | More prostate cancers were detected in the screening group (8.2% vs. 4.8%). The proportion of men with cancer with a Gleason score of 7 or more was 27.8% in the screening group and 45.2% in the control group. The adjusted (for interim analyses) rate ratio for death from prostate cancer in the screening group vs. the control group was 0.80 (95% CI: 0.65, 0.95, p=0.01). Mortality rates began to diverge after 7 to 8 years and continued to do so. To prevent one prostate-cancer death, 1410 (95% CI: 1142–1721) men would need to be screened and 48 additional subjects would need to be treated.
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | Lu-Yao GL, Albertsen PC, Moore DF et al. Outcomes of Localized Prostate Cancer Following Conservative Management. JAMA 2009; 302(11):1202–9. | To evaluate the outcomes of clinically localized prostate cancer managed without initial attempted curative therapy in the PSA era. | Retrospective | 14,516 1992–2002 SEERS registry FU: median = 8.3 yrs | Conservative management | 10-year overall survival, cancer-specific survival, and major cancer-related interventions. | Ten-year disease-specific mortality for men aged 66 to 74 for moderately differentiated disease was 60% to 74% lower than earlier studies: 6% (95% CI: 4%, 8%) in the contemporary PSA era (1992–2002) versus 15% to 23% reported in studies of earlier eras (1949–1992).
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | * Shao Y-H, Albertsen PC, Roberts CB et al. Less is more: Risk profiles and treatment patterns among men diagnosed as having prostate cancer and a prostate-specific antigen level below 4.0 ng/ml. Arch Intern Med 2010; 170:1256–61. Invited commentary by Hoffman RM, Zeliadt SB, The cautionary tale of PSA testing, pp. 1262–3. | To describe the risk profiles and treatment patterns of patients with prostate cancer and PSA levels below 4 ng/ml at the time of diagnosis. | Retrospective | 123,934 2004–2006 16 SEERS registries FU: Unclear | Radical prostatectomy, brachytherapy, external beam radiation therapy, conservative management | Active treatment (surgery or radiation therapy) | Men with PSA levels below 4 ng/dl made up 14% of new prostate cancer cases. 54% of them had low-risk disease, and 97.3% had T1 or T2a disease. More than 75% received active treatment, comparable to rates among those with PSA levels between 4.0 and 20.0 ng/ml. In the low PSA group, treatment occurred more often among the screen-detected cancer even though these patients were less likely to have high-grade disease (OR, 0.67; 95% CI: 0.60, 0.76).
| Eggener SE, Mueller A, Berglund RK et al. A multi-institutional evaluation of active surveillance for low risk prostate cancer. J Urol 2009; 181:1635–41. | To evaluate the actuarial rates and predictors of remaining on active surveillance, the incidence of cancer progression, and the pathological findings of delayed radical prostatectomy. | Retrospective | 262 1991–2007 4 ctrs in US and Canada FU: Median (IQR) = 29 mos (15, 52); 19% of pts had > 5 yrs follow-up | Active surveillance, followed by radical prostatectomy for some pts. | Probability and predictors of remaining on active surveillance, incidence of cancer progression, and pathological findings of delayed radical prostatectomy | Patients underwent second biopsy to confirm initial findings before starting active surveillance. They were also 75 years old or younger and had a life expectancy of more than 10 years. 2- and 5-yr probabilities of remaining on active surveillance were 91% and 75%, respectively. Predictors of leaving active surveillance were having cancer on the second biopsy (HR 2.23, 95% CI: 1.23, 4.06; p=0.007) and more cancerous cores from the 2 biopsies combined (p=0.002). Age, PSA, clinical stage, prostate volume, and number of total biopsy cores sampled were not predictors. 43 of 262 pts underwent delayed treatment, and 95% of those did not have disease progression at a median followup 23 mos after treatment. Also, predictors of delayed treatment were apparently identified by univariate Cox regression; no multivariable analysis was performed.
| * Klotz L, Zhang L, Lam A, Nam R, Mamedov A, Loblaw A. Clinical results of long-term follow-up of a large, active surveillance cohort with localized prostate cancer. J Clin Oncol 2009; 28:126–31. | Update and reanalysis of cohort first reported in 2002; objective is to evaluate active surveillance, with decision to intervene based on PSA kinetics and/or histologic progression. | Prospective, single arm study | 450 1995–2003 FU: Median = 6.8 yrs. | Active surveillance; patients offered definitive treatment if PSA doubling time < 3 yrs, Gleason score progression to 4 + 3 or greater, or unequivocal clinical progression (palpable node). | PSA doubling time, Gleason upgrade, reclassification to higher risk, cause-specific survival, overall survival | 92% were T1 – T2a; 85% had PSA ≤ 10 ng/ml at baseline; and 83% had Gleason score ≤ 6. Median age was 70.3 yrs. 71% were favorable risk by D’Amico criteria. 21.6% of patients died, with 10-year overall survival of 68% (95% CI: 62%, 74%). There was no difference in overall survival between patients still on surveillance and those treated radically. 5 men died of prostate cancer; all had been reclassified as higher risk and offered radical treatment. 135 men discontinued surveillance, with 14 due to personal preference and 8 unknown; the most common reasons were short PSA doubling time (n=65) and grade progression (n=36). The most common treatment was radiation therapy plus ADT, followed by surgery and ADT alone. The hazard ratio for non-prostate cancer to prostate cancer is 18.6.
| Hugosson J, Carlsson S, Aus G et al. Mortality results from the Goteburg randomised population- based prostate- cancer screening trial. Lancet 2010; published online 1 July. Comment by Neal DE, also published online 1 July. | To assess the effects of inviting individual to undergo PSA screening every 2 years. | RCT but participants randomized before invited to participate. Authors state that this allows them to gauge acceptance of screening program as well as its impact on prostate cancer mortality at a population level. | 19,904 1994 Goteborg, Sweden FU: 14 years | PSA screening every 2 years | Prostate-cancer mortality | In the experimental group invited to undergo PSA screening, 76% participated at least once and 11.4% were diagnosed with prostate cancer. The cumulative incidence of prostate cancer was higher in the screened group than in the control group (12.7% vs. 8.2%; HR 1.64, 95% CI: 1.50, 1.80, p<0.0001) Median follow-up after diagnosis was 6.7 years (IQR: 3.1–9.5) in the screening group and 4.3 yrs (IQR: 2.1–7.1) in the control group. The proportion having curative treatment was similar between the two groups, but the percentage with low risk disease at diagnosis was 6.1% in the screening group vs. 2% in the control group. The cumulative risk of death from prostate cancer at 14 years was 0.5% in the screening group versus 0.9% in the control group (rate ratio: 0.56; 95% CI: 0.39–0.82; p=0.002). The rate ratio of prostate cancer death among the screening group who underwent PSA testing and the control group was 0.44 (95% CI: 0.28–0.68; p=0.0002), whereas the rate ratio of prostate cancer death among the screening group who did not undergo PSA testing and the control group was 1.05 (95% CI: 0.62–1.78; p=0.84). Overall, to prevent one cancer death, 293 (95%CI: 177–799) men needed to be screened and 12 diagnosed. NOTE: No effort was apparently made to determine whether any men in the control group underwent PSA screening; nor is it clear how common that is likely to be in the Swedish health care system. Neal pointed out that these results might differ in countries, such as the US, with a higher pre-existing level of PSA use; and as the authors and Neal state, longer followup is needed.
| Rosario DJ, Lane JA, Metcalfe C et al on behalf of ProtecT Study Group. Contribution of a single repeat PSA test to prostate cancer risk assessment: Experience from the ProtecT study. Eur Urol 2008; 53:777–84. | To determine whether a single repeat PSA test can help discriminate cancer from non- cancer-related PSA elevation among men with initial PSA of 3 to 19.9 ng/ml | Analysis of RCT data | 4102 (7.6% of sample in trial) 2002–2006 Multicenter in UK FU: Not relevant | None | Presence of cancer on biopsy | Men with 20% drop in PSA on second test had lower risk of cancer (OR=0.43; 95% CI: 0.32, 0.52; p<0.001) and of high-grade cancer (OR=0.29; 95% CI: 0.19, 0.44; p<0.001). The effect of percentage reduction was greater in younger men (≤ 60 yrs). However, no level of PSA reduction confidently predicted absence of cancer (area under ROC curve for % change in PSA is 0.647 for any prostate cancer and 0.739 for high grade prostate cancer, compared to other men in sample; area under ROC for initial PSA = 0.624 and 0.708, respectively). But risk reduction of high grade cancer would decline from 4% to 0.5%, 6% to 2%, and 15% to 2% for men ≤60 yrs with initial PSA of 3.0–3.99, 4.0–5.99, and ≥6 ng/ml, respectively.
| Freedland SJ, Hotaling JM, Fitzsimons et al. PSA in the new millennium: A powerful predictor of prostate cancer prognosis and radical prostatectomy outcomes —results from the SEARCH database. Eur Urol 2008; 53:758–64. Discussion on pp. 765–6. | To examine the prognostic significance of preoperative PSA to predict pathological stage and biochemical progression among men undergoing radical prostatectomy. | Multivariable prognostic analysis | 912 2000–2006 Multicenter at VA hospitals FU: Median PSA follow-up = 26 mos | Radical prostatectomy | Tumor stage, biochemical progression | Higher initial PSA levels (stratified as < 10, 10.0–19.9, or ≥ 20 ng/ml) are associated with increased odds of extracapsular extension, positive surgical margins, and seminal vesicle invasion and increased risk of biochemical progression. Among men with initial PSA < 10 ng/ml, higher initial PSA within this range is associated with positive surgical margins and higher risk of biochemical progression. Both analyses account for multiple clinical preoperative characteristics. Adjusting for multiple comparisons was not mentioned. Authors note that PSA doubling time may be more strongly associated than biochemical recurrence with prostate cancer death.
| Concato J, Jain D, Lis WW, Risch HA, Uchio EM, Wells CK. Molecular markers and mortality in prostate cancer. BJUI 2007; 100:1259–63. | To report on contemporary experience among men on active surveillance. | Retrospective ; descriptive and prognostic analysis | 321 1991-? 1 institution in US FU: Median = 3.6 yrs | Active surveillance | Active treatment | 24% received definitive treatment, with median time to treatment of 3 yrs. Two- thirds had clinical evidence of disease progression, while one-third were treated because of personal choice without signs of disease progression. Median PSA doubling time was 6.7 yrs. PSAD at diagnosis and increase in Gleason grade on repeat biopsy were significant predictors of time to treatment.
| Stattin P, Holmberg E, Johansson J-E et al on behalf of National Prostate Cancer Register (NCPR) of Sweden. Outcomes of localized prostate cancer: National Prostate Cancer Register of Sweden follow- up study. J Natl Cancer Inst 2010; 102:1–9. | To assess prostate cancer mortality and risk of death from competing causes in patients in the NPCR of Sweden follow-up study with low- or intermediate-risk prostate cancer. | Retrospective | 6,849; 2,686 low risk (T1, Gleason 2–6, serum PSA <10 ng/ml) 1997–2002 National in Sweden FU: median = 8.2 yrs | Surveillance (active or watchful waiting), radical prostatectomy, or radiation therapy | Death from prostate cancer, competing causes, or all causes. | Among low risk patients, the calculated 10-year prostate-cancer-specific mortality was 2.4% (95% CI: 1.2%, 4.1%) in the surveillance group (n=1,085) and 0.7% (95% CI: 0.3%, 1.4%) in the curative intent group (prostatectomy and radiotherapy; n=1,601). Among both intermediate- and low-risk patients, the 10-year risk of dying from competing causes was 19.2% (95% CI: 17.2%, 21.3%) in the surveillance group and 10.2% (95% CI: 9.0%, 11.4%) in the curative intent group. Although the authors tried to account for selection bias in the choice of treatment with the data available, they state the efforts “were not sufficient to compensate for the confounding by indication to treatment by treatment selection.”
| Fradet V, Kurhanewicz J, Cowan JE et al. Prostate cancer managed with active surveillance: Role of anatomic MR imaging and MR spectroscopic imaging. Radiol 2010; 256:176–83. | To determine the prognostic role of MR and MR spectroscopic imaging, compared to transrectal ultrasonography, at diagnosis in disease progression among patients on active surveillance. | Retrospective ; all three diagnostic tests repeated in each patient | 114 1992–2007 1 institution in US FU: Median=59 mos | Active surveillance | Changes in PSA velocity, Gleason grade, or treatment regimen | Adjusted multivariable models indicated that presence of a lesion suggestive of cancer on MR imaging had a hazard ratio of 4.0 (95% CI: 1.1, 14.9) for a Gleason score upgrade on subsequent biopsy. This was the only statistically significant finding, i.e., MRI was not indicative of other outcomes, and other imaging techniques were not significantly associated with the outcomes. Other statistics, such as sensitivity and specificity were not reported. The authors note that imaging techniques have advanced since these tests were done and that MR imaging at 1.5T is more accurate for larger than for smaller lesions.
| Radwan MJ, Yan Y, Luly JR et al. Prostate- specific antigen density predicts adverse pathology and increased risk of biochemical failure. Urol 2007; 69:1121–7. | To determine whether PSA density is an independent predictor of adverse pathologic findings and biochemical recurrence and whether it outperforms PSA. | Prospective, prognostic analysis | 1,327 1990–2003 1 institution in US FU: Median = 31 mos. | Biopsy followed by radical prostatectomy | Seminal vesicle invasion, extracapsular extension, positive surgical margins, biochemical recurrence | PSA density was measured using both ultrasound and pathology to estimate prostate volume. In a multivariable analysis also including biopsy Gleason score and clinical stage, both density measures were independent predictors of all outcomes. Pathologic PSAD is a stronger predictor than ultrasound PSAD, although pathological PSAD can only be measured after surgery. Ultrasound PSAD had a slightly higher C index for some outcomes than PSA, including extracapsular extension (0.695 vs. 0.683) and positive surgical margins (0.640 vs. 0.613). The authors suggest the need to develop more accurate estimates of prostate volume using ultrasound.
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Donnelly BJ, Saliken JC, Brasher PMA, et al. A randomized trial of external beam radiotherapy versus cryoablation in patients with localized prostate cancer. Cancer 2010; 115:4695–704 and 116:323– 30. Editorial by WR Lee on pp. 270–2. | To compare cryoablation to external beam radiotherapy in localized prostate cancer patients. | Randomized, unblinded, noninferiority trial, stratified by biopsy tumor classification and Gleason score. | 244 12/97-2/03 1 institution in Canada FU: Median=100 months | ADT using LR- RH plus cryotherapy OR external beam RT | Disease progression, disease-specific survival, overall survival, quality of life. Failure defined as biochemical failure, radiologic evidence of disease, or initiation of further prostate cancer treatment. Repeat cryotherapy within 6 mos was not considered treatment failure. | Observed difference in disease progression = 0.2% (95% CI: −10.8%, 11.2%). Cannot rule out inferiority, defined a priori as 10%. Cryotherapy patient reported more acute urinary dysfunction, which improved over time; the cryotherapy group reported poorer sexual function from 3 to 36 months, when the study ended. Trial closed prematurely because of diminishing patient accrual.^**^
| Dahl DM, Barry MJ, McGovern FJ et al. A prospective study of symptom distress and return to baseline function after open versus laparoscopic radical prostatectomy. J Urol 2009; 182:956–65. | To conduct a more detailed examination of the functional outcomes of open and laparoscopic prostatectomy | Prospective, concurrent, single institution | 206 6/03–6/04 1 institution in US FU: 1 yr | Series of questionnaires (Symptom Distress Scale, UCLA Prostate Cancer Index, Prostate Cancer Outcomes Study, and SF- 36) for consecutive patients undergoing open vs. laparoscopic radical prostatectomy | Return to baseline levels for continence, erectile dysfunction, or physical function | Tx groups similar on measured variables. No statistically significant differences in return to baseline levels between the treatment groups. More complications among laparoscopic patients but number low in both Tx groups. 1 death in open prostatectomy group of MI one week post-discharge; 2nd died in accident 8 mos later. Authors conclude similar functional outcomes from both procedures.
| Giberti C, Chiono L, Gallo F, Schenone M, Gastaldi E. Radical retropubic prostatectomy versus brachytherapy for low-risk prostatic cancer: A prospective study. World J Urol 2009; 27:607–12. | To compare the oncological and functional outcomes reported with radical retropublic prostatectomy versus brachytherapy among low risk prostate cancer patients. | RCT | 200 (26 of them lost to follow-up by 5 yrs) 5/99–10/02 Italy FU mean=68.2 mos (range: 60, 102 mos | Bilateral nerve sparing radical retropublic prostatectomy vs. brachytherapy | Biochemical disease-free survival rate, pre- vs. post- scores on IPSS (International Prostate Symptom Score), IIEF (International Index of Erectile Function)-5, EORTC-QLQ- C30/PR25), rates of erectile function recovery and postop urinary disorders. | Similar 5-year biochemical disease- free survival rates (91.0% vs. 91.7%). Postop urinary symptoms significantly greater and more persistent in brachytherapy group, but erectile function better. However, by 5 years no significant difference between treatment groups. Authors note need for larger studies with longer followup to confirm findings.
| SPCG-4: Bill- Axelson A, Holmberg L, Filen F et al. Radical prostatectomy versus watchful waiting in localized prostate cancer: The Scandinavian Prostate Cancer Group- 4 randomized trial. J Natl Cancer Inst 2008; 100:1144–54 | To determine whether the absolute and relative benefits of surgical treatment would increase during longer follow up. | RCT | 695 1989–1999 Scandinavia FU: 12 yrs | Radical prostatectomy vs. watchful waiting | Prostate cancer death; metastases | More prostate deaths and distant metastases in watchful waiting group. Group difference in cumulative incidence of prostate deaths and distant metastases stable after 10 years. Limitation: Not among a population where most cancer detected through PSA screening as in US.
| D’Amico AV, Chen M-H, Renshaw AA, Loffredo B, Kantoff WP. Risk of prostate cancer recurrence in men treated with radiation alone or in conjunction with combined or less than combined androgen suppression therapy. J Clin Oncol 2008; 26:2979–83. | To determine the risk of recurrence among men with localized but unfavorable-risk prostate cancer randomized to radiotherapy or radiotherapy plus androgen deprivation therapy. | RCT | 206; 1995–2001 Unclear FU: median=98.4 mos | Radiotherapy ± androgen deprivation therapy | PSA recurrence (PSA > 1.0 ng/ml and a PSA that increased by greater than 0.2 ng/ml at 2 consecutive visits after treatment) and time to PSA recurrence | Use of ADT reduced the risk of recurrence (adjusted hazard ratio=0.81; 95% CI 0.72, 0.92; p=0.001) with each additional month of ADT use. Increasing PSA level; Gleason score of 8, 9, 10; and clinical category 2 disease all statistically significantly associated with increased risk of recurrence.
| Ferrer M, Suarez JF, Guedea F et al. Health- related quality of life 2 years after treatment with radical prostatectomy, prostate brachytherapy, or external beam radiotherapy in patients with clinically localized prostate cancer. Int J Radiation Oncology Biol Phys 2008; 72:421–32. | To compare treatment impact on HRQOL among patients with localized prostate cancer. | Longitudinal, prospective | 614 FU: 2 yrs | Radical prostatectomy vs. 3D-CRT vs. brachytherapy. | Responses to SF-36, Functional Assessment of Cancer Therapy (General and Prostate- Specific), Expanded Prostate Cancer Index Composite (EPIC), American Urological Association Symptom Index. | HRQOL initially deteriorated after all treatments and then partially recovered. After accounting for clinical variables, compared to brachytherapy at 2 years radical prostatectomy patients had worse EPIC sexual summary and urinary incontinence scores; and 3DCRT patients had worse EPIC bowel, sexual, and hormonal summary scores. On the other hand, radical prostatectomy patients had significantly better EPIC urinary irritation scores than brachytherapy patients.
| Freedland SJ, Sun L, Kane CJ et al. Obesity and oncological outcomes after radical prostatectomy: Impact of prostate- specific antigen-based prostate cancer screening: Results from the Shared Equal Access Regional Cancer Hospital and Duke Prostate Cancer Databases. BJUI 2088; 102:969–74. | To indirectly test the hypothesis that PSA-based screening is biased against obese men due to hemodilution of PSA and therefore results in delayed diagnosis and poor outcome beyond the biological link between obesity and aggressive prostate cancer. | Retrospective database study | 3,389 1988–2008 Multicenter Follow-up: Median = 4.5 or 4.8 yrs, depending on database | Radical prostatectomy for men with PSA-detected cancers (cT1c) or with abnormal digital rectal examinations (cT2/T3) | Disease grade, positive surgical margins, biochemical progression | Body mass index (BMI) was associated with high-grade disease and positive surgical margins regardless of clinical stage. When stratified by stage, higher obesity related to greater cohorts among men with cT1c disease but not with cT2/T3 disease. Among men with T1c disease, the association between BMI and biochemical progression was limited to men treated in 2000 or later but not before that. All these results are statistically significant.
| Sanda MG, Dunn RL, Michalski J et al. Quality of life and satisfaction with outcome among prostate- cancer survivors. N Engl J Med 2008; 358:1250–61. | To identify determinants of HRQOL after primary treatment of prostate cancer and to measure their effects on satisfaction with treatment among patients and their partners | Survey | 1,201 pts and 625 partners 2003–2006 Multicenter FU: Before treatment and 2, 6, 12, 24 mos after | Prostatectomy, brachytherapy, or external beam radiation therapy | Patient reported measures from the Expanded Prostate Cancer Index Composite (EPIC-26 or EPIC-Partners) and Service Satisfaction Scale for Cancer Care (SCA or SCA-P) | HRQOL results varied with treatment. ADT lowered QOL in a number of domains for radiotherapy patients (brachytherapy or external beam). Treatment-related symptoms were exacerbated by obesity, large prostate size, high PSA, and older age. Black patients reported lower satisfaction with treatment outcomes overall. Changes in HRQOL were significantly associated with degree of outcome satisfaction among patients and their partners.
| Buron C, Le Vu B, Cosset J-M et al. Brachytherapy versus prostatectomy in localized prostate cancer: Results of a French multicenter prospective medico- economic study. Int J Radiation Oncology Biol Phys 2007; 67:812–22. | To prospectively compare HRQOL, patient-reported treatment-related symptoms, and costs of brachytherapy versus radical prostatectomy | Survey | 435 2001–2002 Multicenter in France FU: Before treatment and 2, 6, 12, 18, 24 mos after | Brachytherapy versus radical prostatectomy (14% laparoscopic, 86% retropubic) | Patient outcomes reported from the EORTC QLQ-C30 and P25 | Using multivariable analysis to account for potential confounders (including use of ADT but not surgical approach) and adjusting for multiple comparisons, changes from baseline were examined for each treatment group. Just after treatment, the global HRQOL change favored brachytherapy (13.5 points; p<0.0001); 2 months after treatment, there was no statistically significant difference between treatment groups in global score change (−4 points; p=0.2720); by 6 months and up to 24 mos, the global score change slightly favored radical prostatectomy (−7.5 points; p ranges from 0.0164 to 0.0379 over the time period). Urinary incontinence was more frequent for radical prostatectomy than brachytherapy over all time periods. Other urinary problems, fecal incontinence, and rectal bleeding were more common with brachytherapy. Results for sexual effects did not take into account use of ADT, which were to be published in a later paper.
GAP 3: FACTORS WITH IMPACT ON DECISION- MAKING | Jang TL, Bekelman JE, Liu Y et al. Physician visits prior to treatment for clinically localized prostate cancer. Arch Intern Med 2010; 170:440– 449. | To evaluate how visits to specialists and PCPs by men with localized prostate cancer are related to treatment choice. | Registry and claims data analyses | 85,088 1994–2002; areas covered by SEER program FU: ~9 mos post-diagnosis | Specialty of physicians visited after diagnosis | Primary therapy received (radical prostatectomy, androgen deprivation, radiotherapy, expectant management) | Strong association between type of specialist seen and primary therapy chosen. About one-fifth of patients see a PCP between diagnosis and treatment, and they were more likely to have expectant management.
GAP 3: FACTORS WITH IMPACT ON DECISION- MAKING | (1) Vickers AJ, Bianco FJ, Serio AM et al. The surgical learning curve for prostate cancer control after radical prostatectomy. J Natl Cancer Inst 2007; 99:1171–7. (2) Bianco FJ, Vickers AJ, Cronin AM et al. Variations among experienced surgeons in cancer control after open radical prostatectomy. J Urol 2010; 183:977–83. | To determine the learning curve for performing radical prostatectomy. | Retrospective | (1) 7,765 pts, 72 surgeons; (2) 7,725 pts, 54 surgeons 1987–2003; Multicenter US FU: Median = 3.9 yrs | Radical prostatectomy | Biochemical recurrence | (1) Learning curve is steep and does not plateau until 250 cases. After accounting for potential confounding variables, predicted probabilities of recurrence at 5 years were 17.9% (95% CI: 12.1%, 25.6%) for surgeons with 10 prior operations; 10.7% (95% CI: 7.1%, 15.9%) for surgeons with 250 prior operations (difference = 7.2%; 95% CI: 4.6%, 10.1%; p<0.001). The results were robust to sensitivity analysis, including restricting analysis to patients treated between 2000 and 2003. (2) Heterogeneity in outcomes persists even among high volume surgeons (40 or more cases). The adjusted, 5-year biochemical recurrence rate was less than 10% among 7 experienced surgeons, while it was more than 25% among another 5 experienced surgeons.
GAP 3: FACTORS WITH IMPACT ON DECISION- MAKING | Vickers AJ, Savage CJ, Hruza M et al. The surgical learning curve for laparoscopic radical prostatectomy: A retrospective cohort study. Lancet Oncol 2009; 10:475– 80. Editorial by Nelson JB, pp. 437–9. | To determine the learning curve for performing laparoscopic radical prostatectomy. | Retrospective | 4,702 1/1998–6/2007; multinational FU: Median = 1.7 yrs | Laparoscopic radical prostatectomy | Biochemical recurrence | Slow learning curve for surgeons until after 250 such surgeries performed. 5- yr risk of biochemical recurrence is 17% for surgeons completing 10 laparoscopic prostatectomy; 16% after 250 surgeries; and 9% after 750 surgeries (adjusted for case mix). Recurrence is greater for surgeons who previously performed open radical prostatectomies. Learning curve is different shape for open radical prostatectomy, with sharp improvement earlier on. Follow-up is short. Editorial notes the need to investigate means to hasten learning process for surgeons inexperienced in this technique and suggests regionalization of care so that fewer patients are treated with less experienced surgeons.
| Spencer BA, Miller DC, Litwin MS et al. Variations in quality of care for men with early-stage prostate cancer. J Clin Oncol 2008; 26:3735–42. | To measure the quality of prostate cancer care nationally using the American College of Surgeons cancer registry | Cross-sectional based on hospital chart review and RAND quality of care criteria | 2,775 cases, extrapolated to 55,160 cases using SUDAAN 2001–2006; National (US) | Radical prostatectomy or external beam radiation therapy | Compliance with quality of care criteria | Overall compliance > 70% for structural and pretherapy disease indicators but lower for documentation of pretreatment functioning (46.4– 78.4%), surgical pathology (37.1– 86.3%), radiation technique (62.6- 88.3%) and followup (55%). Regional variations detected. Higher compliance at teaching/research hospitals and comprehensive cancer centers than at community cancer centers. No racial differences detected.
| Sommers BD, Beard CJ, D’Amico AV, Kaplan I, Richie JP, Zeckhauser RJ. Predictors of patient preferences and treatment choices for localized prostate cancer. Cancer 2008; 113:2058–67. | To examine determinants of patients’ preferences for health states related to prostate cancer and whether those preferences or other factors predict treatment choice | Survey using time-tradeoff approach and multivariable predictive analyses | 167; 2004–2007; 4 academic medical practices in Boston Follow-up: None | Radical prostatectomy, external beam radiotherapy, brachytherapy, hormonal therapy, watchful waiting, undecided | QALYs associated with erectile dysfunction, urinary incontinence, bowel problems, and metastatic prostate cancer; and predictors of treatment choice at time of survey | QALYs were highest for urinary incontinence (0.906), followed by erectile dysfunction (0.923), bowel/rectal discomfort (0.859), and metastatic prostate cancer (0.651). In other words, patients were more willing to accept shorter survival in turn for avoiding metastatic cancer than for avoiding urinary incontinence. The only predictor of all conditions was age, with older men more willing than younger men to exchange shorter survival for the lack of those conditions. The strongest predictor of treatment choice was the specialty of the physician (radiation oncology or urology) seen at the time of enrollment in the study.
| Macefield RC, Lane JA, Metcalfe C et al. Do the risk factors of age, family history of prostate cancer or a higher prostate specific antigen level raise anxiety at prostate biopsy? Eur J Cancer 2009; 45:2569–73. | To examine impact of age, family history of prostate cancer, or PSA on patients’ anxiety at biopsy. | Survey using Hospital Anxiety and Depression Scale; part of ProtecT trial | 4,198 Multicenter in UK FU: Mean time between initial PSA test and biopsy = 54.8 days. | Biopsy | Anxiety score of 8 or more | Older men were less anxious at biopsy than younger men, but younger men had a greater decrease in anxiety between PSA and biopsy. Neither family history of prostate cancer nor significantly elevated PSA level was associated with a higher anxiety level at biopsy or a greater change in anxiety between PSA test and biopsy. However, the number of patients with a positive family history was small.
| Aronowitz JN, Crook JM, Michalski JM et al. Inter- institutional variation in implant activity for permanent prostate brachytherapy. Brachytherapy 2008; 7:297–300. | To determine whether there is interinstitutional consensus regarding the parameters of an ideal implant. | Retrospective, comparative study among institutions | 3 institutions, 136 implants Not reported; Multicenter in Canada and US FU: Not relevant | Brachytherapy | Utilization of seeds and implanted activity. | Despite agreement on implant philosophy, target volume, and dosimetric constraints, there were statistically significant differences in the number of seeds and total implant activity. The variation was greater for small glands.
| Hack TF, Pickles T, Bultz BD, Ruether JD, Degner LF. Impact of providing audiotapes of primary treatment consultations to men with prostate cancer: A multi-site, randomized, controlled trial. Psycho-Oncol 2007; 15:543–52. | To systematically examine the efficacy of providing men with prostate cancer with an audiotape of their primary treatment consultation. | RCT | 425 pts and 15 radiation oncologists 2001; 4 centers in Canada FU: 12 wks | Standard care, consultation audiotaped but audiotape not given to pt; audiotape given to pt; or pt offered audiotape. Pts also surveyed using Control Preferences Scale, the Patient Perception Scale; Audiotape use and satisfaction questionnaire; Informed Communication Scale, Profile of Mood States (POMS), and Functional Assessment of Cancer Therapy (FACT-P). | Perceived degree of information provision, audiotape satisfaction and use, communication satisfaction with oncologist, mood state, and cancer-specific quality of life | Of the patients receiving the audiotape, 65.4% listened to the whole tape and 57.4% had someone else listen to at least part of it. Patients who received it reported having been given significantly more disease and treatment information in general and more information about treatment alternatives and side effects. Audiotape benefit was not significantly associated with patient satisfaction with communication, mood state or quality of life 12 weeks after consultation, or being given the choice of receiving the audiotape. Patients who listened to the audiotape rated the intervention highly.
| Davison BJ, Goldenberg SL, Wiens KP, Gleave ME. Comparing a generic and individualized information decision support intervention for men newly diagnosed with localized prostate cancer. Cancer Nursing 2007; 30:E7–E15. | To compare a generic and individualized approach to providing decisional support to men newly diagnosed with localized prostate cancer. | RCT and surveys | 324; Not reported; 1 institution in Canada FU: 6 wks | View general videotape on early stage prostate cancer with or without additional part of computer program individualized based on medical information from physician’s referral. | Measures of decision control, satisfaction, and decision conflict at baseline and after treatment decision made | Group with individualized information more satisfied with type, amount, and method of providing information, and role played in treatment decisionmaking with their physician. No difference between groups with regard satisfaction with treatment choice after decision made. Both groups also played more active role in treatment decisionmaking than initially preferred.

** Although title refers to “localized” prostate cancer, eligible participants include those with T2 or T3 cancer and no evidence of lymph node or distant metastases. The authors explain “there was no unanimity among the trial clinicians regarding clinical staging (at least 3 opinions)...if a patient had no palpable abnormalities but had positive biopsies in the gland bilaterally, then his biopsy tumor classification was bT2C. If the biopsies revealed microscopic extraprostatic extension of seminal vesicle involvement, then the biopsy tumor classification was bT3C.”

* Articles added after last review by Technical Expert Panel.

Table A-2 Ongoing trials

Research Gap | Study | Study objective (group by this) | Research design | Sample size; Years; Location; Follow-up | Treatment(s) | Outcomes | Status
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | Pre-Operative Gleason Score and PSA and Clinical Stage in Predicting the Risk of Failure in Patients Undergoing Radiation Therapy for Localized Prostate Cancer; UCSF; PI: Mack Roach, MD; NCT00769223 | Studying the Gleason score, PSA level, and cancer stage in predicting outcome in patients who have undergone radiation therapy for localized prostate cancer. | Multivariable prognostic analysis | 3500 2/93-2/13; treated with RT at SF General Hospital or VAMC-SF 1987–2006 | RT ± hormonal Tx | Evaluate the value of the pre- operative Gleason score, prostate-specific antigen level, and clinical stage in predicting the risk of failure and death in patients who have undergone radiotherapy for localized prostate cancer | Recruiting
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | Active Surveillance in Prostate Cancer: A Prospective Cohort Study; PI: Jeri Kim, MD; MD Anderson Cancer Ctr; NCT00490763 | Find out if men who have a type of prostate cancer that has been classified as “low risk” can safely not be treated for the disease | Prospective cohort study | 650 2/06-2/20; MD Anderson FU: 5 yrs | Active surveillance | Disease progression rate | Recruiting
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | Multi-Institutional Inter-SPORE Prostate Biomarker Study; Memorial Sloan-Kettering Cancer Ctr; PI: James Eastham, MD; NCT00574899 | To identify and evaluate prostate biomarkers that will provide exact information regarding the likelihood of a recurrence (prediction) of prostate cancer. | Observational: case-control | 700; 5/07-5/10; Multicenter US | Collect DNA samples from men with localized prostate cancer scheduled for radical prostatectomy or RT | Collect and contribute biologic specimens to Inter-SPORE Prostate Biomarker Study for men with clinical localized prostate cancer scheduled to get standard of care therapy for localized prostate cancer, either radical prostatectomy or RT therapy; to participate in the IPBS by conducting a prospective analysis of the prognostic utility of serum hK2 in predicting biochemical recurrence after definitive local therapy for prostate cancer | Recruiting
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | START trial, described under GAP 2
GAP 1: IDENTIFYING WHICH PATIENTS TO TREAT | See control arm of PIVOT trial
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Regional Cryoablation for Localized Adenocarcinoma of the Prostate; MD Anderson Cancer Ctr/Endocare, Inc, Gen-Probe Inc, Firmamed, Envisioneering Medical Technologies; PI: John F. Ward, MD; NCT00877682 | To learn if using cryotherapy to treat only the part of the prostate that contains cancer is an effective treatment for prostate cancer | Safety/efficacy study | 100; 4/09-4/11; Texas FU: 3 yrs | Cryotherapy | Patient Response (Result of biopsy at 6 months after therapy) | Recruiting (not clear whether all patients have localized disease)
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Phase III Trial of Neutron + Photon Radiation Versus Photon + Hypofractionated Intensity Modulated Radiation Therapy in Localized Prostate Cancer; Barbara Ann Karmanos Cancer Inst; PI: Jeffrey D. Forman, MD, FACR; NCT00258466 | Studying different types of radiation therapy to compare how well they work in treating patients with stage I, stage II, or stage III prostate cancer. | RCT | 300; 5/05-11/06 (primary outcome measure); Michigan FU: 5 yrs+ | Neutron radiotherapy over 15–45 minutes 5 days a week for 2 weeks followed by photon radiotherapy over 15–45 minutes 5 days a week for 5 weeks vs. photon radiotherapy over 15–45 minutes 5 days a week for 5 weeks followed by hypo- fractionated photon irradiation over 15–45 minutes 5 days a week for 2 weeks. | Occurrence of chronic grade 2 or higher toxicity as measured by RTOG/EORTC late morbidity scoring scheme at 1, 4, 8, and 12 months after treatment, then every 6 months for 5 years, then annually; Disease free survival at 1, 4, 8, and 12 months after treatment, then every 6 months for 5 years, then annually. | Study completed; follow-up continuing. Includes T1, T2, and T3 (latter not included in this project)
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Prostate Cancer: Multicentric Study Comparing Carcinological and Functional Results of Surgery; Université Paris XII; PI: Claude Abbou, PU-PH; NCT00502723 | To show that radical prostatectomy by laparoscopic way could obtain carcinological results not lower than those with radical retropubic surgery. | Phase III, non- randomized | 1440 12/07–7/12 France FU: 3 yrs | Radical retropubic prostatectomy versus radical laparoscopic prostatectomy | For each type of surgery, carcinological (percentage of positive surgical margins, percentage of capsular crossing); functional (urinary continence, sexuality, quality of life) at 2 years; pre and post operational morbidity at 36 mos; economic (hospitalization) | Recruiting
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Conventional or Hypofractionated High Dose Intensity Modulated Radiotherapy for Prostate Cancer: CHHIP; Institute of Cancer Research, UK: PI: David P. Dearnaley, MD, FRCP, FRCR; NCT00392535 | Studying the side effects of three schedules of intensity- modulated radiation therapy and compares how well they work in treating patients with localized prostate cancer | RCT | 2,163 10/02-9/12 Multicenter UK FU: 15 yrs | Conventional versus hypo- fractionated high dose IMRT | Acute and late radiation- induced side effects, freedom from recurrence, development of metastases, recommencement of hormonal therapy for disease recurrence, DSS, OS, QOL, health econ, models of normal tissue and tumor control | Recruiting (says clinical stage T1b- T3a, N0, M0, but locally confined disease)
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Pilot Evaluation of High Dose-Rate Brachytherapy ± Image-Guided Intensity Modulated Hypofractionated External Radiotherapy for Localized Prostate Cancer; Mayo Clinic; PI: Thomas Pisansky, M.D. | To study side effects and efficacy of treating patients with internal brachytherapy with or without image- guided IMRT | Phase II | 142; 8/08-12/10 1 institution in US FU: 5 yrs | High Dose-Rate Brachytherapy ± Image-Guided Intensity Modulated Hypofractionate d External Radiotherapy | Tolerability using CTCAE (Common Terminology Criteria for Adverse Events) v. 3.0, dose-adverse event parameters for organs at risk, quality of life, patient preferences. biochemical and clinical failure, other treatments (e.g., ADT) | Recruiting
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Prostate Cancer Intervention Versus Observation Trial (PIVOT), Minneapolis VA Med Ctr; PI: Tim Wilt M.D., M.P.H.; ISRCTN007644 | To determine whether radical prostatectomy or expectant management is more effective in reducing mortality and extending life. | RCT | 731; 06/04-01/10; US | Radical Prostatectomy Versus Palliative Expectant Management | Prostate specific cancer mortality, quality of life, occurrence or recurrence of symptoms and need for cancer treatment | Recruitment and followup completed; data now being cleaned; expect results ~mid-2011. NOTE: Palliative expectant management in PIVOT trial is less aggressive surveillance and treatment than active surveillance in PROTECT trial. CITATION: Wilt TJ, Brawer MK, Barry MJ, et al. The Prostate cancer Intervention Versus Observation Trial: VA/NCI/AHRQ Cooperative Studies Program #407 (PIVOT): design and baseline results of a randomized controlled trial comparing radical prostatectomy to watchful waiting for men with clinically localized prostate cancer. Contemp Clin Trials. 2009 Jan;30(1):81–7. Also, other articles in 1990s.
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Prostate testing for cancer and Treatment (ProtecT); Oxford Radcliffe Hospital, Great Britain; PI: Freddie C. Hamdy, MD; ISRCTN 20141297 | To compare alternative treatments | RCT | 2,050 06/01-12/13 Multicenter UK FU: 10+ yrs | Active Monitoring, Radical Prostatectomy, or Radiation Therapy | Survival time as assessed after the first information appointment at 5 years,10 years, and then every 5 years thereafter; disease progression, treatment complications, quality of life, etc. | Recruiting
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Health-Related Quality Of Life In Patients With Low Risk, Localized Prostate Cancer Randomized To Radical Prostatectomy Or Brachytherapy; Beth Israel Deaconess Medical Center, NY; Martin Sanda, MD | Evaluate quality of life in patients undergoing radical prostatectomy or brachytherapy for stage II prostate cancer. | Part of ACOSOG-Z0070 RCT | 500; 09/02-08/09; Multicenter US FU: 10 yrs | Radical Prostatectomy versus Brachytherapy | HRQOL at baseline; 2 and 6 months; 1, 2, 4, 7, 10 years and interaction with treatment modality or disease progression | First stage of data collection complete; results not published.
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | A Phase III Study of Active Surveillance Therapy Against Radical Treatment in Patients Diagnosed With Favourable Risk Prostate Cancer [START]; NCIC Clinical Trials Group (CALGB, ECOG, SWOG); PI: Laurence H. Klotz, MD et al; NCT00499174 | Studying observation to see how well it works compared with radical treatment as an initial intervention in patients with favorable prognosis prostate cancer. | RCT stratified by treatment center, ECOG performance status, disease stage, baseline PSA, and age. | 2,130; 6/07-4/23; Multicenter US | Active surveillance (move to radical treatment if biochemical, clinical, and/or grade progression) versus radical treatment (radical prostatectomy or radiotherapy per pt/physician preferences) | Disease-specific and overall survival, QOL, distant disease free survival, use of ADP, PSA relapse/progression after radical treatment; proportion active surveillance who receive radical treatment; prognostic significance PSA doubling-time prior to diagnosis, prognostic significance molecular markers | Recruiting
GAP 2: COMPARATIVE EFFECTIVE- NESS OF DIFFERENT TREATMENTS FOR PROSTATE CANCER | Health-Related Quality Of Life In Patients With Low Risk, Localized Prostate Cancer Randomized To Radical Prostatectomy Or Brachytherapy; Beth Israel Deaconess Medical Center, NY; Martin Sanda, MD | Evaluate quality of life in patients undergoing radical prostatectomy or brachytherapy for stage II prostate cancer. | Part of ACOSOG-Z0070 RCT | 500; 09/02-08/09; multicenter US FU: 10 yrs | Radical Prostatectomy versus Brachytherapy | HRQOL at baseline; 2 and 6 months; 1, 2, 4, 7, 10 years and interaction with treatment modality or disease progression | First stage of data collection complete; results not published.
GAP 3: FACTORS WITH IMPACT ON DECISION-MAKING | Treatment Decision-Making in Early Stage Prostate Cancer; Georgetown Univ; PI: KL Taylor; NCT00196781 | To test the effectiveness of a recently developed computer-based program to improve patient knowledge about prostate cancer treatments; also designed to help men clarify their values using a computer-based ‘decision aid.’ | RCT | 168; 9/02-12/05 FU: 12 mos | Computer-based patient education aid ± decision aid. | Treatment satisfaction, quality of life, prostate cancer knowledge, shared decisionmaking | Trial completed; no publications to date. Long period since completion of study, with no apparent publications.