# Abbreviations

ADT: androgen-deprivation therapy
AHRQ: Agency for Healthcare Research and Quality
BCBSA: Blue Cross and Blue Shield Association
bNED: biochemical non-evidence of disease
CER: comparative effectiveness review
COI: conflict of interest
DRE: digital rectal examination
EPC: Evidence-based Practice Center
HIV: human immunodeficiency virus
HRQOL: health-related quality of life
IMRT: intensity-modulated radiotherapy
N: sample size
OS: overall survival
PICOS: patients, interventions, comparators, outcomes, settings
PIVOT: Prostate Cancer Intervention Versus Observation Trial
PFS: progression-free survival
PROTECT: Prostate Testing for Cancer and Treatment
PSA: prostate-specific antigen
RCT: randomized, controlled trial
RFP: request for proposals
RP: radical prostatectomy
RT: radiotherapy
T1: tumor stage 1
T2: tumor stage 2
TEC: Technology Evaluation Center
TEPP: Technical Expert and Patient Panel