# Results

## Contribution of Recent Publications and Ongoing Studies

No rotator cuff research knowledge gap was adequately addressed with the recently published outcomes literature or ongoing studies identified through ClinicalTrails.gov (see Appendix B Table 1). As with the studies in the original systematic review, most recent publications covered surgical technique or surgical repair augmentation rather than the many other approaches to rotator cuff treatment. However, a small proportion of ongoing studies focus on the broader questions in rotator cuff treatment, such as rehabilitation timing and intensity, nonoperative versus operative care, and demographic factors in successful nonoperative care.

## Research Needs

All professional stakeholders and one consumer completed the web-based prioritization exercise for a 100 percent participation rate.

Stakeholders identified, discussed, and prioritized the fundamental methodological and scientific issues that need to be investigated and resolved in order to meaningfully advance outcomes knowledge for patients with rotator cuff tears. Due to the breadth of unresolved research questions in rotator cuff outcomes, the prioritized lists of Methods and Scientific Issues identify both unresolved thematic areas within the domains of rotator cuff diagnosis and treatment as well as several specific research questions.

### Methods Issues

The methods issues in rotator cuff outcomes are aimed at improving consistency in the conduct of clinical trials, estimating treatment effects in terms of clinically important differences in outcomes, and reliably assessing the magnitude of rotator cuff pathology. These issues were considered by stakeholders as fundamental to enable future research to adequately address scientific rotator cuff tear research questions. To accomplish that aim, the suggested mechanism to resolve Methods issues was a consensus conference.

Table 1 provides a summary of stakeholder rankings for methods issues. Issues that scored above 4 for both weighted and unweighted scores are considered high priority. Based on ranking, the highest ranked issues stakeholders identified in need of consensus were determining the amount of change in key outcomes that is clinically (as opposed to statistically) significant for patients (weighted score = 9), and the selection of a set of outcomes assessment tools to be used in all studies (weighted score = 8). At the other end of the range, issues given a score of 0 related to measuring provider-related factors that may contribute to patient outcomes.

Table 1 Stakeholder ranking of methods issues

Methods Issue Question | Weighted | Unweighted | Related PICO Element
Measurement
Which validated outcomes instruments should be used in all studies? | 8 † | 7 † | O
What is a minimal clinically important difference in key outcomes? | 9 † | 7 † | O
Which promising and/or controversial interventions should be studied? | 4 † | 4 † | I
What set of consistent definitions of rotator cuff pathology, including concomitant pathology, should be used across providers and imaging reports? | 4 † | 4 † | P
What diagnostic imaging (MRI, ultrasound, surgical inspection, arthrogram) best determines the extent of rotator cuff pathology at baseline, and when is it indicated? | 5 † | 5 †
What imaging is best to evaluate cuff integrity post-surgery, and when is it indicated? | 4 † | 4 †
Which imaging is best for cuff tears superimposed on pre-existing pathology? | 1 | 1
What provider training and experience thresholds are required for accurate imaging interpretation (tear classification) for rotator cuff for pathology? | 0 | 0
How should ‘cuff integrity’ be defined for (1) nonoperative/preoperative and (2) postoperative patients? | 3 | 3
What constitutes a good or acceptable repair? | 3 | 3
What surgeon factors are associated with better operative repair and/or better outcomes? | 0 | 0
Should minimum thresholds, such as number of cases or training, be required for complex repairs or revisions? | 0 | 0
Which patient factors should be collected at baseline across all studies? | 5^†^ | 5 † | P
Design and Reporting
Should classification of study participants be pathology based or impairment based? | 3 | 3
Which patient groups (for example, acute/chronic, older active/inactive, worker’s compensation) should special care be given to assure representation in research samples? | 2 | 2
What should the minimum followup duration be? Define “long-term.” | 2 | 2
Identify additional outcomes data sources (health plan, CMS, VA, other) and develop guidelines for use and reporting (STROBE, other). Is a registry necessary to accrue sufficient patients to examine natural history, baseline factors, and outcomes? | 4 † | 3

CMS = Centers for Medicare and Medicaid Services; MRI = magnetic resonance imaging; PICO = population, intervention, comparison, outcome; STROBE = strengthening the reporting of observational studies in epidemiology; VA = U.S. Department of Veterans Affairs

† Item was ranked in the top quartile. Each stakeholder had six stars to assign to issues deemed high priority. Up to three stars could be assigned to any one issue.

Stakeholder prioritization generally agreed, whether using weighted scores (total number of assigned stars per item) or unweighted scores (the number of stakeholders assigning at least one star). No noticeable differences in ranking patterns were discerned across type of stakeholder. (See Appendix B Table 2 for detailed ranking scores.)

Stakeholders did not define a single patient population as priority for studies of rotator cuff treatments, although subgroups such as older individuals with underlying degenerative changes in the shoulder and patients on Workman’s Compensation were mentioned in discussions. Instead, stakeholders recommended that all studies collect critical variables that define both the degree and age of rotator cuff injury and the patient in whom it occurred.

### Scientific Research Questions

Table 2 provides a summary of the prioritized stakeholder rankings for unresolved scientific issues. Most of the scientific gaps reflect focused theme areas rather than specific research questions. The quality and quantity of the literature to date is thin, and the research gaps are broad. Therefore, stakeholder discussions often focused on areas of knowledge gaps as opposed to specific research questions.

Table 2 Stakeholder ranking of scientific research questions

Scientific Research Question | Weighted | Unweighted | Related PICO Elements
Overarching Questions
Which patients do best with nonoperative treatment? | 9 † | 7 † | P
Which tears require surgery? | 6 † | 5 † | P
What is the threshold for surgery, given the rotator cuff tear severity/grade? | 2 | 2
How does concomitant pathology or patient age modify a surgical threshold? | 5 † | 3
How long should a good outcome persist after operative or nonoperative intervention and should these recovery duration expectations differ by treatment approach? | 1 | 1
How should recovery duration expectations differ in older patients? | 0 | 0
What is the overall value of rehabilitation/adjunctive care? | 4 | 3
How should rehabilitation (operative and nonoperative) strategies, timing, and intensity, differ by the tear characteristics, patient age, mechanism of injury, type of repair and work issues/worker’s compensation? | 8 † | 6 † | P
How does the timing of passive/active/resistive exercise impact tissue healing in post-operative rehabilitation? | 4 | 4 †
What is the impact of range of motion and strength on outcomes? | 1 | 1
What is the natural history of rotator cuff tears? What variables (risk factors) are associated with progression of fatty atrophy and tear size? | 7 † | 5 † | P
Which patient and cuff tear factor(s) most strongly predict poor outcomes after surgery? | 6 † | 5 † | P
Which patient subgroups (age, tear-based, functional limitation-based) should be identified in RCTs/clinical studies, and which are too heterogeneous to combine for outcomes comparisons? | 0 | 0
What patient demographics and clinical profiles are important? (Age, health habits/smoking, hand dominance, worker’s compensation, specific comorbidities). | 3 | 3
How do tear characteristics affect outcomes: size, age/duration of pathology, pre-existing/chronic changes, mechanism of injury? | 4 | 4 †
How do psychosocial factors such as depression, socioeconomic status, motivation/self-efficacy, fear-avoidance, and coping mechanisms modify outcomes? | 4 | 4 †
Nonoperative Questions
Which nonoperative interventions and which comparisons should be studied? (Physical therapy, exercise (supervised vs. home-based), cortisone injections, massage therapy, acupuncture, other). | 4 | 4 †
Nonoperative vs. Operative Questions
Which nonoperative vs. operative treatment comparisons are most important among patients whose condition may benefit from either approach? (Which patients do equally well when treated nonoperatively or operatively?) | 2 | 1
Operative Questions
Given surgery is indicated, when is early (vs. delayed) surgery indicated? | 2 | 2
Does cuff integrity predict patient-centered outcomes? Is a “successful” (intact) rotator cuff repair necessary? | 2 | 2
Why does surgery often result in improved outcomes, even with evidence of repair failure? | 0 | 0
What is the effectiveness or comparative effectiveness of different surgical decisions, such as approach, technique, or associated procedures? | 5 † | 4 † | I/C
Who benefits from repeat procedures and when should revision repair be attempted? | 1 | 1
What is the effectiveness of adjunctive/biologic technologies such as protein-rich plasma, growth factors, stem cells, reinforcement meshes or patches? | 3 | 3
Which surgical procedures (tenotomy, muscle transfer, reverse total shoulder replacement, other) should be considered for irreparable rotator cuff tears? | 3 | 3
What information will best help a patient choose a provider and treatment path? | 4 | 3

PICO = population, intervention, comparison, outcome; RCT = randomized controlled trial

† Item was ranked in the top quartile. Each stakeholder had 9 stars to assign to questions deemed high priority. Up to 3 stars could be assigned to any one issue.

High-priority areas are those that scored in the top quartile, 4.75 for weighted scores and 4 for unweighted scores. The highest priority scientific issues include understanding which patients do best with nonoperative treatment (weighted score = 9), determining the optimal rehabilitation strategies (weighted score = 8), understanding the natural history of rotator cuff tears (weighted score = 7), and distinguishing which rotator cuff tears require surgery and which factors predict poor recovery after surgery (weighted score = 6).

A greater number of stakeholders assigned multiple stars to scientific questions than methods issues, so more differences are seen between the weighted and unweighted rankings. This accounts for the differences in the quartile statistics, and the addition of the patient age or concomitant pathology as modifier for a surgical threshold.

There were also discernable differences in the prioritization patterns between the categories of stakeholders. Orthopedic researchers/clinicians drove the high ranking of the question on the natural history of rotator cuff tears, while the physical therapy and massage therapy researcher/clinicians and the nonclinician stakeholders drove the high ranking for determining the optimal rehabilitation strategies. While the term “natural history” typically refers to what happens over time to the rotator cuff and surrounding structures and pain without treatment, stakeholders agreed that the natural history questions for rotator cuff tears should also encompass what happens over time with or in spite of treatment. In either case, studies of the progression of rotator cuff pathology over time are extremely limited and much remains unknown.

Interestingly, nonclinician stakeholders drove the appearance of the question on the effectiveness of different surgical techniques. Neither the orthopedic researcher/clinicians nor the physical therapy or massage therapy researcher/clinicians ranked surgical technique studies as high priority. (See Appendix B Table 3 for more detail.)

The highest priority scientific question of when to utilize a nonoperative versus operative treatment approach is notable. It suggests a great deal of provider uncertainty in the treatment of patients with tears that fall in the mid-range of the spectrum of rotator cuff pathology. In general, stakeholders suggested that among patients with extreme or minor pathology, there is less variability in the choice of a class of health care (nonoperative vs. operative) because providers may better agree on which general class of treatment to pursue initially. However, a large proportion of patients with rotator cuff tears could potentially be treated nonoperatively or operatively, and the current literature lacks sufficient information for helping health care providers make those decisions.

Stakeholders noted that despite great pressure in orthopedics to evaluate new, controversial, or promising interventions such as the use of local biologic agents to improve healing after surgery (as evidenced by the quantity of ongoing studies in this area), such therapies are not top priority research agenda items.

## Consumer Priorities

Consumers’ main goal was for rotator cuff treatment to return patients to full physical function. Consumers suggested that patients should be evaluated initially by shoulder-specific providers and specialists to assure that patients receive an accurate clinical diagnosis and plan of care. Serial misdiagnoses delay appropriate treatment and delays may limit some treatment options altogether.

Similar to providers, consumers indicated during conference calls that they lack knowledge about which rotator cuff injuries need surgery, how to find information on highly qualified shoulder providers, and where to get a good initial examination for a potential rotator cuff problem. More importantly, consumers suggested that providers may limit the treatment options they identify for consumers to their own specific preferences (surgery versus other), rather than informing patients of the realm of treatment options for a given pathology and patient situation. Consumers want access to the necessary information to make choices appropriate to their condition and in accordance with their values and care preferences.

## Research Approach Considerations

Strategies to resolve rotator cuff knowledge gaps differ between methods and scientific issues. First, consensus must be reached within and across disciplines on the highest priorities in rotator cuff methods. Then, based on the consensus information, researchers can address the highest priority scientific research gaps by designing and conducting focused, sufficiently-powered clinical studies that use a comparison or control group.

The top three methods issues could be resolved through a consensus conference. Since rotator cuff tears are treated by more than one provider group, a consensus conference ideally would be multidisciplinary with participants to include surgical, nonoperative, and nonallopathic health care providers, radiologists, and researchers with expertise in clinical outcomes, epidemiology, biostatistics, and health services research.

Priority populations for the top scientific questions could also be clarified during a consensus conference. Although stakeholders did identify populations whose outcomes could differ within given treatment approaches, the current research gaps were too broad to focus exclusively on patient subgroups. Still, stakeholders overwhelmingly agreed during the conference calls and in their ranking that greater differentiation of baseline patient characteristics is required to advance the field. This was reflected in six of the seven top-ranked scientific questions pertaining to understanding patient populations.

Since most rotator cuff treatment involves true professional equipoise with no one treatment clearly preferred to another, RCTs are the best research approach for resolving many rotator cuff tear questions related to specific treatments and techniques. RCTs with sufficient sample sizes are able to detect small treatment effects or differences in rotator cuff treatment outcomes because randomization minimizes bias from both observed and unobserved (or unmeasured) variables, giving a clear picture of treatment effects in specific populations. RCTs can be used to compare: (1) strategies and timing for rehabilitation; (2) operative versus nonoperative treatment for patients with rotator cuff tears where there is true equipoise among both types of providers; and (3) surgical techniques. RCTs most often produce valid conclusions and can offer important information about the relative merits of competing treatments within the same or similar rotator cuff patients in highly-controlled treatment settings. However, RCTs can be relatively costly due to study personnel and data collection costs including staff time and patient travel. A second drawback, as with most RCTs, is that results may not be generalizable to the range of patients with rotator cuff tears.

Operative rotator cuff treatment studies may be subject to fewer ethical concerns than investigations of other operative conditions, such as hip fracture, for two reasons. First, the original systematic review found that treatment complications are uncommon, relatively mild and usually not life-threatening. Second, potential ethical dilemmas related to vulnerable patient populations may be less prominent in the rotator cuff investigations suggested in the original systematic review. While rotator cuff problems are common in a wide array of individuals, the prioritized unresolved rotator cuff treatment questions apply to a population of relatively healthy adults, rather than particularly impaired or otherwise unhealthy or frail individuals. However, the use of local, novel biologics and other healing agents may require special consideration depending on the stage of product development and regulatory approval.

The most important question in rotator cuff treatment is “what to do and for whom?” There is great variability in patient characteristics, rotator cuff tear characteristics, pre-existing degenerative changes about the shoulder, the condition of the surrounding tissues to provide shoulder stability, and categories of surgical and nonsurgical treatments including specifics within those categories. The number of RCTs required to meet all of those needs with sufficient patient samples could be staggering. Therefore, focused observational research studies within the topic of “what for whom” that are sufficiently powered and meticulously conducted can incrementally advance the field.

For rotator cuff tear studies, cohort studies can offer more generalizable information than results from most RCTs. Prospective cohort studies enroll and follow patients over time to assess outcomes. The advantages of cohort studies include having a comparison group without randomizing patients, having a sufficient number and variety of patients, such as patient demographics and tear characteristics, to comment on outcomes differences within subgroups, and generally possessing greater similarity to real-world practice than RCTs. Cohort studies are also better suited to make comments about recovery trajectories and the natural history of rotator cuff tears. These studies compare one or more groups of individuals who have a risk factor or treatment to “control” individuals who lack “exposure” to that risk factor treatment.

While cohort studies allow for comparisons of outcomes in rotator cuff patients treated by varying regimens, caution must be exercised because of inherent risk of bias in interpreting outcomes in nonrandomized studies. Typically, unmeasured variables account for what treatments the patients received, which may also be responsible for any differences in outcomes, rather than the treatments themselves. Controlling for the effects of unmeasured variables is harder to accomplish through statistical techniques. While cohort studies allow for comparison of outcomes in patients treated by varying regimens, caution must be exercised because of the inherent risk of bias in interpreting outcomes in nonrandomized studies. Treatment selection biases can come from patient and provider factors and need to be considered in the selection of variables to collect and use for analyses. For example, some surgeons may choose one rotator cuff procedure over another because of personal preference or familiarity, rather than based on patient factors. Cohort studies also include disadvantages similar to RCTs, such as high costs of following patients over time and dealing with attrition. Similar to RCTs, recruitment of large numbers of patients (at least hundreds) are needed to examine effects in patient subgroups.

Several stakeholders suggested a rotator cuff registry, which would make it possible to follow patients over time and collect a large number of variables at baseline and over time. In order to track subjects over time, treating practitioners need to be involved in recruiting patients into the effort. Additionally, resources must be dedicated to tracking and contacting subjects using internet-based techniques in order to optimize followup information contained in the registry. Though no control group is utilized with a registry, the data collected would provide insight into recovery trajectories and natural history studies. However, the outcomes collected may be limited and based on funding and other important limitations, such as the number of participating health care sites and the research focus of the main investigators. Further, registries follow a select subset of patients, often those who live near the high-volume health care sites involved. Such patients and their treatment results may not reflect the outcomes that could be obtained among rural or lower volume providers and settings.