# References

1 Seida J, Schouten J, Mousavi S, et al. Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears. Comparative Effectiveness Review No. 22. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-02-0023.) AHRQ Publication No. 10-EHC050. Rockville, MD. Agency for Healthcare Research and Quality. July. 2010. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Moher D, Schulz K, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. Annals of Internal Medicine. April. 17. 2001;134(8):657-62. [pmid: 11304106].
3 Department of Commerce. Office of the Chief Information Officer WebPage. The Paperwork Reduction Act and Information Collections Policy. www.whitehouse.gov/sites/default/files/omb/inforeg/statpolicy/standards_stat_surveys.pdf. Accessed August 31, 2010.