# Executive Summary

## Background

The systematic literature review, Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears,1 was conducted by the University of Alberta Evidence-based Practice Center (EPC) in 2010 to examine the effectiveness of various nonoperative and operative treatments for adults with partial- or full-thickness rotator cuff tears. The review addressed six Key Questions (KQs) that compared patient outcomes after various operative approaches and techniques, early versus late surgical repair, operative versus nonoperative treatment and between various nonoperative therapies. The outcomes included health-related quality of life, return to work, pain, shoulder function, rotator cuff integrity, and complications. However, adverse treatment effects and the impact of baseline patient and injury characteristics on outcomes were also included.

The systematic review was unable to fully answer the KQs using the rotator cuff literature from 1990 through August 2009 because the literature was sparse and of low to moderate quality. Of the 137 studies included, less than one-fifth were clinical trials and more than half were uncontrolled studies. The literature limitations included low study quality, disparate treatments and outcomes, small sample sizes, incomplete followup, and a heavy focus on surgical technique or approach research over other aspects of rotator cuff treatment (82 percent of studies). The randomized clinical trial (RCT) literature was of particularly low quality with high risk of bias from the manner in which the studies had been conducted. The observational study literature was of moderate quality but often lacked control for the effects of potential confounding factors on outcomes.

For most rotator cuff interventions, only sparse data were available, which precluded firm conclusions about the value of any single approach in the optimal management of rotator cuff tears. Although most interventions showed positive effects, few improvements were of clinical importance. The paucity of evidence on early versus delayed surgery (one trial) was a noted concern because of the lack of evidence available for providers and patients on the important choice of initial nonoperative management or immediate surgical repair.

The review concluded that more research and higher quality research are needed to determine the relative effectiveness of rotator cuff treatments.

This Future Research Needs follow-on project used stakeholder feedback to identify and prioritize the current research knowledge gaps in rotator cuff treatment in order to improve outcomes after rotator cuff tears. The focus of this project was on treatment and post-treatment outcomes rather than complications, because the systematic review found that rotator cuff treatment complications were infrequent and often not clinically important.

This Executive Summary provides a brief synopsis of the project. Details can be found in the full report (www.effectivehealthcare.ahrq.gov).

## Methods

We searched Medline from September 2009 through August 2011 for RCTs and observational studies with comparison groups to determine if new publications partially filled the previously-identified knowledge gaps. We searched ClinicalTrials.gov for relevant ongoing studies. Searches were conducted using simple search terms such as “rotator cuff tear.” Trial records were reviewed for relevance based on adults with acute or chronic partial- or full-thickness rotator cuff tears. Publications and study protocols were assessed for relevance at the title and abstract level; applicable studies were retrieved, reviewed, and matched to one or more rotator cuff research gaps.

The Minnesota EPC team of researchers and orthopedic surgeons augmented the list of research gaps from the Rotator Cuff systematic review to include gaps that were identified before the literature and ongoing studies update. Additions were made to the Methods and Scientific lists of unresolved rotator cuff research issues.

We convened a 12-member stakeholder group with broad representation from orthopedic surgeon-researchers, nonoperative health care providers, nonoperative clinician-researchers, professional organization representatives, federal research funders, payers, and consumers. We sought stakeholders who were familiar with the current rotator cuff research and had knowledge of research designs since many research gaps were methodological in nature.

Between September and November 2011, stakeholders participated in at least one of four conference calls to discuss the state of rotator cuff research and provide feedback on the initial list of research gaps. Consumers were convened on a separate call to provide a relaxed atmosphere for open discussion and to minimize potential communication barriers due to medical terminology. All other calls involved stakeholders according to their scheduling convenience. Prior to the conference calls, stakeholders were provided a document on the background and purpose of the project, the original report’s Executive Summary, the initial list of research gaps, a list of new publications and ongoing studies, the Effective Health Care Selection Criteria for New Research, and an agenda.

Email was used for all other contact. A combined conference call summary was sent to all stakeholders with a revised research gap list based on their input.

We subsequently conducted a prioritization activity with 10 stakeholders using Web-based ranking software developed by the Research Triangle Institute/University of North Carolina EPC. All ten stakeholders were provided a limited number of stars with which to indicate their selection of high priority issues or topics. Six stars were available to indicate priorities among the 17 methods issues. Nine stars were available for the 27 scientific questions. A stakeholder could assign up to three stars for an issue or item deemed highly important.

Priority scores were calculated by summing the stars assigned by all stakeholders to a methods or scientific topic. High priority was assigned to those items in the top quartile of scores. Weighted and unweighted scores were calculated.

## Results

No rotator cuff research knowledge gap was adequately addressed with the recently published outcomes literature or ongoing studies identified through ClinicalTrials.gov

All professional stakeholders and one consumer completed the prioritization exercise for a 100 percent participation rate. Table A provides methods issues and scientific questions with priority rankings in the top quartile.

Table A Stakeholder rankings of methods issues

Methods Issue Questions | Weighted Score | Related PICO Element
Measurement
What is a minimal clinically important difference in key outcomes? | 9 | O
Which validated outcomes instruments should be used in all studies? | 8 | O
What diagnostic imaging (MRI, ultrasound, surgical inspection, arthrogram) best determines the extent of rotator cuff pathology at baseline, and when is it indicated? | 5
Which patient factors should be collected at baseline across all studies? | 5 | P
Which promising and/or controversial interventions should be studied? | 4 | I
What set of consistent definitions of rotator cuff pathology, including concomitant pathology, should be used across providers and imaging reports? | 4 | P
What imaging is best to evaluate cuff integrity post-surgery, and when is it indicated? | 4
Design and Reporting
Identify additional outcomes data sources (health plan, CMS, VA, other) and develop guidelines for use and reporting (STROBE, other). Is a registry necessary to accrue sufficient patients to examine natural history, baseline factors, and outcomes? | 4
Scientific Research Questions
Which patients do best with nonoperative treatment? | 9 | P
How should rehabilitation (operative and nonoperative) strategies, timing, and intensity, differ by the tear characteristics, patient age, mechanism of injury, type of repair and work issues/worker’s compensation? | 8 | P
What is the natural history of rotator cuff tears? What variables (risk factors) are associated with progression of fatty atrophy and tear size? | 7 | P
Which tears require surgery? | 6 | P
Which patient and cuff tear factor(s) most strongly predict poor outcomes after surgery? | 6 | P
What is the effectiveness or comparative effectiveness of different surgical decisions, such as approach, technique, or associated procedures? | 5 | I/C

CMS = Centers for Medicare and Medicaid Services; MRI = magnetic resonance imaging; PICO = population, intervention, comparison, outcome; STROBE = strengthening the reporting of observational studies in epidemiology; VA = U.S. Department of Veterans Affairs

The highest priority methods issues in need of consensus were determining the amount of change in key outcomes that is clinically (rather than statistically) significant, and the selection of a set of outcomes assessment tools to be used in all studies. Ranking patterns were similar across types of stakeholders.

The highest priority scientific issues include understanding which patients do best with nonoperative treatment, determining the optimal rehabilitation strategies, understanding the natural history of rotator cuff tears, and distinguishing which rotator cuff tears require surgery. Here differences in scientific prioritization patterns were noted between categories of stakeholders. Orthopedic researchers/clinicians drove the high ranking of the question on the natural history of rotator cuff tears, whereas the physical therapy and massage therapy researcher/clinicians and the nonprovider stakeholders drove the high ranking for determining the optimal rehabilitation strategies. Neither the orthopedic researcher/clinicians nor the physical therapy or massage therapy researcher/clinicians ranked the surgical technique comparisons as high priority; nonprovider stakeholders assigned higher scores to surgical technique comparisons. The use of local biologic agents to improve healing after surgery was not deemed a priority research item.

Stakeholders did not define a priority patient population for rotator cuff studies, although subgroups such as older individuals with underlying degenerative changes in the shoulder and patients on workers compensation were identified during the calls. Rather, stakeholders recommended that all studies collect critical variables that define both the degree and age of rotator cuff injury and the patient in whom it occurred.

The highest consumer priority was full return to function after rotator cuff tears. Consumers recommended that patients seek initial evaluations from shoulder-specific providers to assure an accurate diagnosis because serial misdiagnoses are common and may delay appropriate treatment. Consumers lack knowledge about which rotator cuff injuries need surgery and how to find information on good shoulder providers who will provide a good clinical examination for a potential rotator cuff problem. Consumers suggested that the treatment options identified by providers may be limited to the preference of the specific provider (surgery versus other), rather than encompass the realm of suitable options. Consumers want information and education to enable them to make informed care choices in accordance with their values and care preferences.

Strategies to resolve rotator cuff knowledge gaps differ between methods and scientific issues. First, consensus must be reached within and across disciplines on the highest priorities in rotator cuff methods. Then, based on the consensus information, researchers should address the highest priority research gaps by designing and conducting focused, sufficiently-powered clinical studies that use a comparison or control group.

The top three methods issues could be resolved through a consensus conference. Since rotator cuff tears are treated by more than one provider group, a consensus conference would require multidisciplinary participation of surgical, nonoperative, and nonallopathic health care providers, radiologists, and researchers with expertise in clinical outcomes, epidemiology, biostatistics, and health services research.

Priority populations for the scientific questions could also be identified during a consensus conference. Stakeholders overwhelmingly agreed during the conference calls and in their ranking that to advance the field will require greater differentiation of baseline patient characteristics.

Since most rotator cuff treatment involves true professional equipoise with no one treatment clearly preferred to another, RCTs are the best research approach for resolving many rotator cuff questions. RCTs should compare: (1) strategies and timing for rehabilitation; (2) operative versus nonoperative treatment for patients with tears where there is true equipoise among types of providers; and (3) surgical techniques. However, RCT results may not be generalizable to the range of patients with rotator cuff tears. Rather, RCTs can offer important information about the relative merits of competing treatments within the same or similar patients in highly-controlled treatment settings.

Prospective cohort studies enroll and follow patients over time to assess outcomes. Patients are enrolled based on their condition and demographic factors, with treatment decisions made at the discretion of the providers. Cohort studies, often directed by epidemiologists, typically enroll more patients than orthopedic RCTs. The advantages of prospective cohort studies include having a comparison group without randomizing patients, having sufficient number and variety of patients to comment on outcomes differences within subgroups, and generally possessing greater similarity to real-world practice than RCTs. Cohort studies can also make comments about recovery trajectories and the natural history of rotator cuff tears. While cohort studies allow for comparison of outcomes in patients treated by varying regimens, caution must be exercised because of the inherent risk of bias in interpreting outcomes in nonrandomized studies.

Several stakeholders suggested a rotator cuff registry to follow patients over time. The data collected would provide insight into recovery trajectories and natural history studies. Registries follow a select subset of patients, often those who live near the high-volume health care sites involved. Such patients and their treatment results may not reflect the outcomes that could be obtained among rural or lower volume providers and settings.

## Discussion

A select group of rotator cuff tear experts, professional organization representatives, funders, payers, and consumers, showed a high level of agreement in identifying the overarching question of “which treatment is best for which patients, and when.” In the context of unresolved rotator cuff questions, surgical technique questions were superseded by questions about which patients actually require surgery. Consistent with conference call themes, stakeholder rankings emphasized that research undertaken to address the scientific questions should be conducted with an eye to moving the field forward.

Answers to the scientific questions will depend on resolving the methodological issues that have thus far plagued the literature. To improve the quality of rotator cuff research, and ultimately of patient care, consistent definitions and terms for rotator cuff pathology are essential across nonoperative, operative, and diagnostic/radiologic providers. Future clinical investigation should utilize comparison groups where possible. Additionally, multidisciplinary consensus on methods issues will enhance the comparability and utility of research findings so that the most successful treatments can be applied at the right time and in the right patients.

A primary concern of consumers across the spectrum of rotator cuff evaluation and treatment was the way in which provider specialization, or lack thereof, affected rotator cuff diagnoses and treatments. Although brief summary comments were made on provider effects in the systematic review, stakeholders in this project identified as issues potential provider quality and expertise differences in treatment and outcomes across the full range of diagnostic, nonoperative, and operative providers. Provider quality issues may emerge as the rotator cuff research foundation becomes more clearly established, particularly among patients with complex pathology.

This project’s strength lies in the multidisciplinary perspective brought by the broad stakeholder participation. Stakeholders from orthopedic surgery, physical therapy, massage therapy, research program funders, provider organizations, and consumers, contributed insights toward a cohesive set of recommendations. Consumer input during and separate from the provider stakeholder calls illuminated the needs of consumers in rotator cuff research and care choices, and the impact of the current substandard rotator cuff tear research base on patient care. Even with 100 percent participation, the prioritization activity was limited to a small sample, and the results may not reflect the priorities of the general stakeholder populations.

## Conclusions

This project engaged a broad array of stakeholders to identify and prioritize critical knowledge gaps regarding rotator cuff tear outcomes. Stakeholders identified “which treatment is best for which patient, and when” as the important overarching question.

Since patients with rotator cuff tears are treated by a broad range of health care providers, consensus on the minimum set of outcomes assessment tools to use in clinical studies would best be decided by a multidisciplinary consensus conference. Once consensus is attained on the highest priority methodological issues, scientific investigation in existing gap areas can progress towards resolution.

Using such consensus information, researchers are encouraged to design and conduct focused, sufficiently powered clinical studies that utilize a comparison or control group to address the highest priority research gaps. The ideal format is an RCT. However, the modest sample sizes of most rotator cuff RCTs does not allow for subgroup analyses. Consequently, a prospective cohort study may be the best way to determine the influence of a variety of patient factors on outcomes, examine the natural history of rotator cuff tears, or compare clinical recovery trajectories that account for baseline patient differences including the magnitude of rotator cuff pathology.

Hence, the systematic review findings along with the prioritized gaps lists provide a roadmap for focusing and advancing rotator cuff research in the United States toward improved patient care.