# Conclusion

This project engaged a broad array of stakeholders to identify and prioritize critical knowledge gaps regarding rotator cuff tear outcomes. Stakeholders identified “which treatment is best for which patient, and when?” as the important overarching question.

Since patients with rotator cuff tears are treated by a broad range of health care providers, consensus on the minimum set of outcomes assessment tools to use in clinical studies would best be decided by a multidisciplinary consensus conference. Once consensus is attained on the highest priority methodological issues, scientific investigation in existing gap areas can progress towards resolution.

Using such consensus information, researchers are encouraged to design and conduct focused, sufficiently powered clinical studies that utilize a comparison or control group to address the highest priority research gaps. The ideal format is an RCT. However, the modest sample sizes of most rotator cuff RCTs does not allow for subgroup analyses. Rather, a prospective cohort study may be the best way to determine the influence of a variety of patient factors on outcomes, examine the natural history of rotator cuff tears, or compare clinical recovery trajectories that account for baseline patient differences, including the magnitude of rotator cuff pathology.

Hence, the systematic review findings along with the prioritized gaps lists provide a roadmap for focusing and advancing rotator cuff research in the United States toward improved care.