# Background

## Context

The 2010 systematic literature review, “Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears,”1 was conducted by the University of Alberta Evidence-based Practice Center (EPC) to examine the comparative effectiveness of various nonoperative and operative treatments for adults with rotator cuff tears. The report was intended for a broad audience, including professional societies for the development of clinical practice guidelines, patients, health care providers, and researchers conducting studies on rotator cuff treatments. The review addressed six Key Questions (KQs) related to treatments for adults with partial- or full-thickness rotator cuff tears. Examined outcomes included health-related quality of life, return to work, pain, shoulder function, rotator cuff integrity, and complications. The review compared patient outcomes after various operative approaches and techniques, early versus late surgical repair, operative versus nonoperative treatment, and between various nonoperative therapies. Additionally, the adverse effects of any treatment approach and the impact of baseline demographic and injury characteristics on outcomes were included.

The six KQs in the 2010 rotator cuff systematic review were:

KQ 1 Does early surgical repair compared with late surgical repair (i.e., nonoperative intervention followed by surgery) lead to improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength?
KQ 2 What is the comparative effectiveness of operative approaches (e.g., open surgery, mini-open surgery, and arthroscopy) and postoperative rehabilitation on improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength?
  - Which operative approach should be used for different types of tears (e.g., partial-thickness or full-thickness; small, medium, large, or massive; with or without fatty infiltration of muscle tissue)?
KQ 3 What is the comparative effectiveness of nonoperative interventions on improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength? Nonoperative interventions include, but are not limited to, exercise, manual therapy, cortisone injections, acupuncture, and treatments and modalities typically delivered by physical therapists, osteopaths, and chiropractors.
  - Which nonoperative treatment approach should be used for different types of tears (e.g., partial-thickness, full-thickness; small, medium, large, or massive; with or without fatty infiltration of muscle tissue)?
KQ 4 Does operative repair compared with nonoperative treatment lead to improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength?
KQ 5 What are the associated risks, adverse effects, and potential harms of nonoperative and operative therapies?
KQ 6 Which demographic (e.g., age, sex, ethnicity, comorbidities, workers’ compensation claims) and clinical (e.g., size/severity of tear, duration of injury, fatty infiltration of muscle) prognostic factors predict better outcomes following nonoperative and operative treatment?
  - Which (if any) demographic and clinical factors account for potential differences in surgical outcomes between patients who undergo early versus delayed surgical treatment?

The systematic review was unable to fully answer the KQs using the rotator cuff literature from 1990 through August 2009 because the literature was sparse with low to moderate methodological quality. Of the 137 studies included in the systematic review, less than one-fifth were clinical trials and more than half were uncontrolled studies. The limitations of the literature included low overall quality of clinical research studies, wide variation in treatments and outcomes, small sample sizes, incomplete outcomes assessments, and a heavy focus on surgical approach or technique over research on other aspects of rotator cuff treatment (82 percent of studies). The randomized clinical trial (RCT) literature was found to be of particularly low quality with high risk of bias from the manner in which the studies had been conducted. The observational study literature was of moderate quality, but often lacked controls for the effects of potential confounding factors on outcomes.

For the overwhelming majority of rotator cuff interventions, only sparse data were available which precluded firm conclusions for any single approach and, more importantly, for the optimal overall management of rotator cuff tears. Although interventions appeared to positively impact clinical outcomes, in cases where interventions could be compared directly, few improvements were of clinical importance. The report found the paucity of evidence (one trial) related to early versus delayed surgery to be of particular concern, because patients and providers must decide whether to attempt initial nonoperative management or proceed immediately with surgical repair. The review concluded that more research and higher quality research is needed to determine the relative effectiveness of rotator cuff treatments.

## Research Evidence Gaps

The report identified numerous comparators with only sparse evidence but for which future research is a priority. Figure 1 shows the analytic framework used for the systematic review, and the inter-relationship between the six KQs and the factors and interventions included in the systematic review.

Figure 1 Analytic framework

NSAID = nonsteriodal anti-inflammatory drug

Figure 1 is a flow diagram illustrating possible clinical paths for patients with rotator cuff tears, showing decision nodes for operatiave or nonoperative treatments to mutiple options within those two choices, and the potential resulting outcomes. It also locates the key questions of the review within the context of the framework.

The systematic review made a number of recommendations for improving future rotator cuff research quality and increasing comparability of results across studies. The goal of the recommendations was to increase the utility of research findings for providers, professional societies, and patients. Seven future research recommendations taken directly from the original rotator cuff systematic review are:

- Primary evidence is needed comparing the effectiveness of early versus delayed surgery, nonoperative versus operative interventions, and between nonoperative treatment options. Future research examining the comparative effectiveness of open, mini-open, or arthroscopic approaches is also a priority, as arthroscopic procedures are more costly and technically difficult.
- All future studies should employ a comparison or control group and should ensure comparability of treatment groups, optimally through the use of randomization.
- Future research should seek to minimize bias by blinding outcome assessors, using validated and standardized outcome assessment instruments, and ensuring adequate allocation concealment (where applicable) and the appropriate handling and reporting of missing data.
- Studies examining the long-term effectiveness of treatments over the course of several years are needed; at the very least, studies should follow patients for a minimum of 12 months.
- To avoid numerous studies on disparate interventions, the interventions and comparisons chosen for study should be guided by consensus regarding the most promising and/or controversial interventions.
- To ensure consistency and comparability across future studies, consensus is needed on outcomes that are important to both clinicians and patients. Moreover, consensus on minimal clinically important differences is needed to guide study design and interpretation of results.
- To permit the appropriate interpretation of results, Future Research Needs to be reported in a consistent and comprehensive manner.

Additionally, the report suggested improving cross-cutting research quality and comparability issues, including improving consistency in research reporting:

“Future research should incorporate design elements to minimize bias in treatment effects including randomization where possible, blinding of outcome assessors, comparability of study groups, and appropriate handling and reporting of missing data. Consensus is needed on clinically and patient-important outcomes, as well as minimum clinically important differences. Consistency across studies is needed in choice of outcomes and measurement tools. Comprehensive and consistent reporting in future studies will allow for more accurate comparisons and the interpretation of findings across studies as well as greater understanding with respect to the applicability of the findings.”

## Future Research Needs for Rotator Cuff Tears

The goal of this project was to use stakeholder feedback to identify and prioritize the current research knowledge gaps in rotator cuff treatment in order to improve outcomes after rotator cuff tears. The project focused on treatment and post-treatment outcomes rather than complications, because the systematic review found that rotator cuff treatment complications were infrequent and often not clinically important.

This project expands and builds on the recommendations of the Alberta EPC to provide further specification and focus for future rotator cuff research efforts. We utilized a health services research perspective throughout this project by augmenting the original list of rotator cuff knowledge gaps with factors that can impact rotator cuff treatment quality and outcomes that were not considered in the original systematic review, such as provider experience, degree of provider specialization and surgical quality.