# Revised List of Rotator Cuff Research Knowledge Gaps

## Revised Rotator Cuff Research Gaps

### 1 Methodological Issues

#### a Measurement

- Outcomes:
  ○ Which validated instruments should be used in all studies?
  ○ What is a minimal clinically-important difference (MCID) in key outcomes?
- Interventions: which promising and/or controversial interventions should be studied?
- Classification of rotator cuff pathology:
  ○ Terminology: Clear and consistent definitions (terms) of rotator cuff pathology across providers and imaging reports is needed, including terms for concomitant pathology.
  ○ What diagnostic imaging best determines the extent of rotator cuff pathology at baseline (MRI, ultrasound, surgical inspection, arthrogram)?
  ○ What imaging is best to evaluate cuff integrity post-surgery?
  ○ Which imaging is best for rotator cuff tears superimposed on pre-existing pathology?
  ○ Tear classification: What provider training and experience thresholds are required for accurate imaging interpretation for rotator cuff for pathology?
- Cuff integrity: Define term for (1) nonoperative/pre-operative and (2) postoperative patients
- Surgical quality: What constitutes a good or acceptable repair?
- Surgeon variability:
  ○ What surgeon factors are associated with better operative repair and/or better outcomes?
  ○ Should minimum thresholds (cases, training) be required for complex repairs or revisions?
- Patient factors: Which factors should be collected at baseline across all studies?

#### b Design and Reporting

- Study design: A comparison/control group should be employed. Randomization is optimal.
- Study conduct: Minimize bias: systematic followup independent of return visits; use independent and blinded outcome assessors, use validated outcomes instruments, conceal allocation, and appropriately handle missing data.
- Classification of study patients: Should it be pathology-based or impairment-based?
- Reporting: Descriptions of specific treatments and reporting of results, including baseline patient differences, needs improvement. CONSORT and STROBE are suggestions.
- Omission of conceptual models: Failure to control for the influence of multiple predictors on outcomes (baseline demographic/comorbidities, cuff/tear-specifics, treatment specifics, surgeon, rehabilitation, etc.) leads to inaccurate (biased) conclusions about intervention effects.
- Sampling issues: Small sample sizes, lack of representativeness (acute/chronic, older active/inactive, worker’s compensation, other understudied groups).
- Long-term outcomes: What should the minimum followup duration be? Define “long-term.”
- Data sources/reporting: Identify additional outcomes data sources (health plan, CMS, VA, other) and develop guidelines for use and reporting (STROBE, other). A registry may be necessary to accrue sufficient patients to examine natural history, baseline factors and outcomes.

### 2 Scientific Issues

#### Overarching Questions

- Treatment and sequence: Which treatments help, and in what order (nonoperative, operative)?
- Surgical indications: Which tears require surgery?
  ○ What is the threshold for surgery, given the rotator cuff tear severity/grade?
  ○ How does concomitant pathology or patient age modify a surgical threshold?
  ○ Who does best nonoperatively?
- Maintenance of outcomes/improved function:
  ○ How long should a good outcome persist after operative or nonoperative intervention and should these recovery duration expectations differ by treatment approach?
  ○ How should recovery duration expectations differ in older patients?
- Rehabilitation:
  ○ What is the overall value of rehabilitation/adjunctive care?
  ○ Timing of rehabilitation (operative and nonoperative): What should be done and when?
    ■ How should rehabilitation strategies, timing and intensity differ by the tear characteristics, patient age, mechanism of injury, type of repair, and work issues/worker’s compensation
  ○ Post-operative rehabilitation:
    ■ What is the role of CPM (continuous passive motion)?
    ■ How does the timing of passive→active→resistive exercise impact tissue healing?
  ○ What is the impact of range of motion (ROM) and strength on outcomes?
- Natural history: What is the natural history of rotator cuff tears? What variables (risk factors) are associated with progression of fatty atrophy and tear size?
- Predictors of outcomes/covariates:
  ○ Which patient and cuff tear factor(s) most strongly predict poor outcomes after surgery?
  ○ Which patient subgroups (age, tear-based, functional limitation-based) should be identified in RCTs/clinical studies, and which are too heterogeneous to combine for outcomes comparisons?
  ○ What patient demographics and clinical profiles are important (age, health habits/smoking, hand dominance, worker’s compensation, specific comorbidities)?
  ○ How do tear characteristics affect outcomes: size, age/duration of pathology, pre-existing/chronic changes, mechanism of injury?
  ○ How do psychosocial factors such as depression, socioeconomic status, motivation/self-efficacy, fear-avoidance, and coping mechanisms modify outcomes?

#### Nonoperative

- Nonoperative treatments: Which intervention and which comparisons should be studied (PT, exercise (supervised vs. home-based), cortisone injections, massage therapy, acupuncture, other)?

#### Nonoperative versus operative interventions

- Which treatment comparisons are most important among patients whose condition may benefit from either approach? (Which patients do equally well when treated nonoperatively or operatively?)

#### Operative

- Operative timing: Given surgery is indicated, when is early (versus delayed) surgery indicated?
- Operative interventions:
  ○ Does cuff integrity predict patient-centered outcomes? Is a “successful” (intact) rotator cuff repair necessary?
  ○ Why does surgery often result in improved outcomes, even with evidence of repair failure?
- Surgical decisions:
  1. Approach: What is the comparative effectiveness of open, mini-open, or arthroscopic approaches?
  2. Technique: What comparisons are warranted, regardless of surgical approach?
  3. Associated procedures: When should associated procedures be performed (distal clavicle excision, biceps tenodesis or tenotomy, Superior Labrum Anterior and Posterior (SLAP) repair, subacromial decompression/acromioplasty?
- Repeat procedures: Who benefits and when should revision repair be attempted?
- Intraoperative/nonoperative adjunctive cuff repair technology: What is the effectiveness of protein-rich plasma (PRP), growth factors, stem cells, reinforcement meshes or patches, or other adjunctive/biologic technologies?
- Irreparable rotator cuff tears: Which surgical procedures (tenotomy, muscle transfer, reverse total shoulder replacement, other) should be considered?

Areas needing multispecialty consensus:

- Indications for imaging of the rotator cuff (initial).
- Post-operative imaging: when is it indicated and which imaging?
- A multidisciplinary guideline or standard of care in the assessment and treatment of rotator cuff tears.