# Prioritization Criteria for Rotator Cuff Future Research Needs

Based on stakeholder input, a set of prioritization criteria was determined based on a modified set of the Agency for Healthcare Research and Quality’s (AHRQ’s) Effective Health Care Program’s Topic Selection Criteria. (Numbering was not altered to facilitate comparison to the original criteria set.) The Importance criteria should include considerations such as uncertainty for decisionmakers, important variation in clinical care, clinical benefits and harms, and high costs. Potential Impact includes the potential for new knowledge and the likelihood the study will inform clinical practice, whether the research addresses inequities, vulnerable and diverse populations, or ethical, legal, and social issues pertaining to the condition. Capacity includes considerations regarding the feasibility of the suggested methods or research question potential success based on possible conference proceedings or study designs.

2. Importance | 2a. Represents a significant disease burden; large proportion or priority population
2. Importance | 2b. Is of high public interest; affects health care decision-making, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular
2. Importance | 2c. Was nominated/strongly supported by one or more stakeholder groups
2. Importance | 2d. Represents important uncertainty for decisionmakers
2. Importance | 2e. Incorporates issues around both clinical benefits and potential clinical harms
2. Importance | 2f. Represents important variation in clinical care, or controversy in what constitutes appropriate clinical care
2. Importance | 2g. Represents high costs due to common use, to high unit costs, or to high associated costs to consumers, to patients, to health care systems, or to payers
4. Potential Impact | 4a. Potential for significant health impact:; - To improve health outcomes; - To reduce significant variation in clinical practices known to be related to quality of care; - To reduce unnecessary burden on those with health care problems
4. Potential Impact | 4b. Potential for significant economic impact:; - To reduce unnecessary or excessive costs
4. Potential Impact | 4c. Potential for change:; - The proposed topic exists within a clinical, consumer, or policymaking context that is amenable to evidence-based change; - A product from the EHC program could be an appropriate vehicle
4. Potential Impact | 4d. Potential risk from inaction:; - Unintended harms from lack of prioritization of a nominated topic
4. Potential Impact | 4e. Addresses inequities, vulnerable populations (including issues for patient subgroups)
4. Potential Impact | 4f. Addresses a topic that has clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups
5. Capacity | 5a. Efficiency (i.e., considering the timing of the need for new evidence, it is likely that a result could be produced in a timely manner)
5. Capacity | 5b. Utilizes existing AHRQ resources or builds desired additional research capacity or decisional support for the EHC Program
5. Capacity | 5c. Costs associated with the likely study design are reasonable considering limited program resources

Adapted from www.ncbi.nlm.nih.gov/books/NBK51239/ Appendix F in Carey TS, Crotty KA, Morrissey JP, et al. Future Research Needs for the Integration of Mental Health/Substance Abuse and Primary Care: Identification of Future Research Needs from Evidence Report/Technology Assessment No. 173 [Internet]. Rockville (MD): Agency for Healthcare Research and Quality (U.S.); 2010 Sep. (Future Research Needs Papers, No. 3.)