# Minnesota Evidence-based Practice Center Rotator Cuff Research Needs Project: Stakeholder Conference Call Information

This memo outlines specific areas where your expert feedback is requested for this AHRQ-funded project. The attached information forms the basis of your upcoming conference call with us, so please review it prior to our call. We are specifically interested in any additions, modifications, or deletions to the list of research knowledge gaps that you would suggest, especially if you believe that the list does not include pressing research issues that hinder the field’s ability to address rotator cuff research questions adequately.

Background: The 2010 University of Alberta EPC report, “Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears,” summarized the rotator cuff outcomes literature from 1990 through 2009, and focused on six Key Questions (KQs) related to rotator cuff treatment options in adults. The KQs are listed on page 2 of this document. The outcomes examined were health-related quality of life, return to work, pain, shoulder function, cuff integrity and complications. Broadly, the review compared outcomes following various operative approaches, after early versus late surgical repair, after operative versus nonoperative treatment and between various nonoperative therapies. It also included adverse effects or harms of any approach, and the impact of baseline demographic and injury characteristics on outcomes. The review found the existing literature to be sparse and of low to moderate quality, rendering many outcomes questions unanswerable. Seven recommendations were made for further research.

This project will expand and build on those recommendations to provide further specification and focus for future research endeavors. The initial report recommendations are listed in the Rotator Cuff Research Knowledge Gaps list.

Project objective: The goal of this project is to use expert/stakeholder feedback to identify and prioritize the current research knowledge gaps in rotator cuff treatment, and recommend the optimal research approaches to best fill those knowledge gaps to improve patient care. The main focus of this project is on treatment and post-treatment outcomes, rather than complications.

What we need from you during the conference call: Please review the attached document, Rotator Cuff Research Knowledge Gaps. The document was generated by content and methodological experts at the MN EPC to summarize the rotator cuff knowledge gaps identified in the 2010 report. The MN EPC expanded the list with additional items identified as issues from a broader health services research perspective. The list is extensive and will need to be reduced to a reasonable number before the prioritization exercise. The Ongoing or Recently Completed Studies document provides information that may or may not help you determine whether a research gap should advance to the prioritization stage. During the call we will discuss:

- What gaps you feel should be added or clarified.
- Which gaps should be excluded from the list due to not meeting a minimum importance threshold?
- If the Ongoing or Recently Completed Studies list complete or if it is missing important studies.

Timeline and Plan: The conference call is scheduled for September 23, 1:00 CDT. A summary of the conference call will be emailed to stakeholders within one week, where you will be given the opportunity to provide any additional comments or clarification. The MN EPC will then draft a final list of research gaps with suggested conference projects, goals, or research designs to address those gaps. Stakeholders will then engage in a ranking procedure by using a web-based prioritization software through which a suggested prioritization list will be generated. A final report will be generated by the MN EPC in September, which will later be posted on AHRQ’s Effective Health Care Web site.

We welcome your participation in this AHRQ-sponsored project, and look forward to working with you. If you have any questions, please feel free to contact Robert Kane or Mary Butler.

## Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears^*^ * The full report is available at: www.effectivehealthcare.ahrq.gov/ehc/products/67/467/CER22_RotatorCuff1.pdf.

AHRQ Pub. No. 10-EHC050-EF, July 2010

The following Key Questions (KQs) were investigated for a population of adult patients with partial- and full thickness rotator cuff (RC) tears:

1. Does early surgical repair compared with late surgical repair (i.e., nonoperative intervention followed by surgery) lead to improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength?
2. What is the comparative effectiveness of operative approaches (e.g., open surgery, mini-open surgery, and arthroscopy) and postoperative rehabilitation on improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength?
  - Which operative approach should be used for different types of tears (e.g., partial-thickness or full-thickness; small, medium, large, or massive; with or without fatty infiltration of muscle tissue)?
3. What is the comparative effectiveness of nonoperative interventions on improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength? Nonoperative interventions include, but are not limited to, exercise, manual therapy, cortisone injections, acupuncture, and treatments and modalities typically delivered by physical therapists, osteopaths, and chiropractors.
  - Which nonoperative treatment approach should be used for different types of tears (e.g., partial-thickness, full-thickness; small, medium, large, or massive; with or without fatty infiltration of muscle tissue)?
4. Does operative repair compared with nonoperative treatment lead to improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength?
5. What are the associated risks, adverse effects, and potential harms of nonoperative and operative therapies?
6. Which demographic (e.g., age, gender, ethnicity, comorbidities, workers’ compensation claims) and clinical (e.g., size/severity of tear, duration of injury, fatty infiltration of muscle) prognostic factors predict better outcomes following nonoperative and operative treatment?
  - Which (if any) demographic and clinical factors account for potential differences in surgical outcomes between patients who undergo early versus delayed surgical treatment?