# Initial List of Rotator Cuff Research Knowledge Gaps

The rotator cuff research recommendations that were made in the original report are organized below in two categories: methodological issues that limit the usefulness of current and future research, and scientific issues that have not been addressed within the literature. Within each subsection, we expanded the original gap list using Minnesota EPC team member expertise, and have labeled those additions by subheading as Additional-(MN EPC).

## 1 Gaps Related to Methodological Issues

### a Measurement Issues

#### Recommendations from original report

- Outcomes: There is inconsistency in measures and a lack of comparability across studies regarding:
  ○ Which measures to use: consensus is needed on outcomes measures that are most important both to clinicians and patients. Validated and standardized outcome assessment instruments should be used where possible.
  ○ What is a minimal clinically-important difference (MCID) in key outcomes: Consensus will assist sample size calculations for future studies.
- Interventions: to avoid numerous studies on disparate interventions, the interventions and comparisons chosen for a study should be guided by consensus regarding the most promising and/or controversial interventions.

#### Additional measurement gaps (MN EPC)

- Classification of rotator cuff pathology: Clinical examination is often unreliable.
  ○ What diagnostic imaging best determines the extent of rotator cuff pathology at baseline (MRI, ultrasound, surgical inspection, arthrogram) and is consensus needed?
  ○ What imaging should be used to evaluate cuff integrity post-surgery for outcomes comparison?
  ○ Does either of these recommendations differ with patient age? (Are tears harder to detect in patients with pre-existing advanced degenerative changes in/about the shoulder?)
- Cuff integrity: cuff integrity should be defined and operationalized. How does this definition differ among pre- and postoperative patients?
- Surgical quality: Consensus should be reached on what constitutes a good or acceptable repair.
- Surgeon factors: What surgeon factors are associated with better operative repair and/or better outcomes? Possible examples include rotator cuff operative case volume (total career or annual), fellowship training, experience per approach, years of general surgical experience, and complication rates. Should repeat rotator cuff repairs and complex procedures be limited to a subset of shoulder surgeons?
- Patient factors: Which factors should be collected at baseline across all studies?

### b Design and Reporting Issues

#### Recommendations from original report

- Study design: Future studies should employ a comparison or control group and should ensure comparability of treatment groups, optimally through the use of randomization.
- Study conduct (internal validity): Future research should seek to minimize bias by blinding outcome assessors, using validated and standardized outcome assessment instruments, and ensuring adequate allocation concealment (where applicable) and the appropriate handling and reporting of missing data.
- Reporting: Results and study quality are often difficult to interpret due to inconsistent or incomplete results reporting. CONSORT and STROBE are suggestions for quality research reporting. Reporting study results in a consistent and comprehensive manner permits appropriate interpretation of results.

#### Additional design and reporting issues (MN EPC)

- Omission of conceptual models: Failure to control for the influence of multiple predictors on outcomes (baseline demographic and comorbidity information, cuff/tear-specifics, intervention, surgeon and rehabilitation, etc.) can lead to inaccurate (biased) conclusions about the effect of specific interventions on outcomes.
- Sampling issues:
  ○ Small sample sizes (MCID consensus is needed).
  ○ Representativeness: acute versus chronic patients, understudied populations (older active, older inactive, others).
- Clinical trajectories: How long should good outcome persist, especially in older patients where rotator cuff tear incidence increases over time? Should expectations differ for operative versus nonoperative interventions?
- Data sources: Are there additional outcomes data sources (large health plan, CMS, VA, other)?
- Administrative databases: Develop guidelines for use and reporting (STROBE, other).

## 2 Gaps Related to Scientific Issues

### Recommendations from original report

- Operative timing: Primary evidence is needed comparing the effectiveness of early versus delayed surgery.
- Nonoperative and operative interventions: Primary evidence is needed comparing nonoperative and operative interventions.
- Nonoperative treatments: Primary evidence is needed comparing different nonoperative treatments.
- Surgical approach: Future research examining the comparative effectiveness of open, mini-open, or arthroscopic approaches is also important, as arthroscopic procedures are more costly and technically difficult.
- Long-term outcomes: Studies examining the long-term effectiveness of treatments over the course of several years are needed; at the very least, studies should follow patients for a minimum of 12 months.
- Rehabilitation: Research is needed to determine optimal post-operative rehabilitation protocol.

### Additional scientific issues (MN EPC)

#### Operative

- Surgical technique: What, if any, technique-specific comparisons are warranted, regardless of surgical approach?
- Post-operative Rehabilitation: How should rehabilitation strategies differ by the size of the cuff tear, type of repair, patient age, mechanism of injury etc.?
- Operative timing: Primary evidence is needed on comparing early versus delayed surgery.
- Operative interventions: Is a “successful” (intact) rotator cuff repair necessary? If a large proportion of rotator cuff repairs fail early (i.e., en route from the operating room to recovery), why does surgery sometimes result in improved outcomes, even with evidence of repair failure? Repeat procedures: Who benefits from repeat repair attempts and when should a repair revision be considered? The impact of this question will grow due to the aging population and the increase in “working retired” population.
- Intraoperative cuff repair adjunctive technology: What is the effectiveness of protein-rich plasma, growth factors, stem cells, reinforcement meshes or patches, or other adjunctive technologies?
- Irreparable rotator cuff tears: Which surgical procedures (muscle transfer, reverse total shoulder replacement, other) should be considered? When should associated procedures be performed (distal clavicle excision, biceps tenodesis or tenotomy, SLAP repair, subacromial decompression [acromioplasty])?

#### Nonoperative

- Nonoperative treatments: Which interventions, and comparisons of interventions, are important to study (PT, cortisone injections, acupuncture, massage therapy, other)?
- Risk Factors: What variables are associated with risk of progression of fatty atrophy and tear size?

#### Overarching Questions

- Longer-term outcomes: What followup duration should be considered minimum? (24 months?)
- Patient age: If differences exist in the types of pathology by age, then age distinctions for Future Research Needs, such as young, middle-age, young-old, and old-old, are important to consider. Applicability of findings for treatment or recovery trajectories for the elderly population is of particular interest.
- Predictors of outcomes/covariates: Further information for applicability would be useful.
  ○ Which patient and rotator cuff tear factor(s) most strongly predict poor outcome after rotator cuff repair?
  ○ Which patient subgroups (age or tear-based) should be identified in RCTs/clinical studies, and which are too heterogeneous to combine for outcomes comparisons?
  ○ What patient demographics and clinical profiles are important: age, health habits, smoking, hand dominance, specific comorbidities?
  ○ How do tear characteristics affect outcomes: size, age/duration of pathology, pre-existing/chronic changes, mechanism of injury?
- Rehabilitation: Controversies continue regarding timing and intensity. How should rehabilitation differ by age of patient, tear characteristics, return to work or other factors?
- Psychosocial factors: How do factors such as depression, socioeconomic status, motivation/self-efficacy, modify outcomes?