# Prioritization Methods and Tools

## Specific Methods

### 1 We formed stakeholder groups with representation from orthopedic surgeon-researchers, nonoperative health care providers and clinician-researchers, professional organizations, federal research funders, payers, and consumers

We formed stakeholder groups from the provider/payer/researcher perspectives as well as consumer representatives. Since the rotator cuff research gaps were both topic-specific and methodological in nature, we sought expert stakeholders who were familiar with the current rotator cuff research and had a working knowledge of research design. We first constructed a general list of the types of health care providers, clinician and basic science researchers, funders and payers that represent various stakeholder groups and perspectives with an interest in rotator cuff outcomes across the spectrum of adult care (acute to chronic, all ages). A list of potential stakeholders was then constructed by the Minnesota Evidence-based Practice Center (EPC) faculty (health services and clinical outcomes researchers, orthopedic surgeon-researchers including an orthopedic shoulder surgeon and multidisciplinary nonoperative physicians). The Technical Expert Panel (TEP) members from the 2010 Alberta EPC rotator cuff systematic review were considered. Two representatives from the American Academy of Orthopedic Surgeons (AAOS) Rotator Cuff Guidelines Work Group were invited. Additional clinicians or clinician-researchers with broad rotator cuff treatment, outcomes and rehabilitation interests were added to include orthopedic shoulder surgery, physical therapy, massage therapy, and a family practice/nonoperative sports medicine physician. We included representatives from the major orthopedic funding agencies (government, orthopedic associations and foundations). In addition to the AAOS, we invited representatives from related professional organizations including the American Shoulder and Elbow Surgeons (ASES), the American Orthopaedic Society for Sports Medicine (AOSSM) and the American Academy of Physical Medicine and Rehabilitation (AAPM&R) the American Massage Therapy Association (AMTA), and the American Physical Therapy Association (APTA). We listed large payers of rotator cuff operative and nonoperative care and industry representatives. Consumers were identified by the Minnesota EPC to represent three varying perspectives on rotator cuff treatment in the United States. This process resulted in a 12- member stakeholder group including orthopedic surgeon-researchers, basic science and clinical outcomes researchers, nonoperative health care providers, professional organizations, federal research funders, health care payers, and consumers.

### 2 We simultaneously performed a search to locate relevant, recently-completed and currently on-going rotator cuff outcomes studies that potentially addressed existing knowledge gaps. The results of this search informed the preliminary list of identified research gaps to which the stakeholders would respond

Search results were combined with the list of identified research gaps from the original systematic review plus Minnesota EPC faculty input in knowledge gap areas that are common to most orthopedic treatments (such as the effects of provider experience or surgical quality on outcomes) to generate a list of specific rotator cuff knowledge gaps. See Appendix A for more search details.

Appendix B Table 1 provides a summary table of the Key Questions (KQs), literature update and ongoing clinical trials list. The list of research gaps identified in the July 2010 systematic review served as the starting point for this project based on the six KQs that were the focus of that report. Column 1 of Appendix B Table 1 lists the KQs (1–6) from the 2010 rotator cuff systematic review. Column 2 provides a short summary of the issue each KQ is aimed at addressing plus a list of “Other knowledge gaps” that were not specifically identified within the KQs but were identified by the Minnesota EPC faculty. Column 3 lists the title, primary author, journal, year and PubMed abstract link for randomized trials that were published after the 2010 systematic review search ended, or that covered minimally-clinically important differences in rotator cuff outcomes from other clinical studies. Column 4 lists ongoing clinical studies listed in clinicaltrials.gov limited to randomized trials, treatments used in the United States or those that used a comparison group or addressed a research gap area with modest methodology rigor.

An augmented, detailed list of rotator cuff research gaps was constructed by the Minnesota EPC project faculty to include additional gaps that were identified before or during the literature and ongoing studies update (Appendix C). Examples of some of the items added for stakeholder discussion and prioritization were the impact of provider experience, degree of provider specialization and surgical quality on outcomes, as well as a clear definition of “rotator cuff integrity” for both nonoperative and postoperative patients. The initial set of research gaps for the stakeholder engagement process is provided below. It includes two theme areas: Methodological Issues that include items related to measurement and study design, and Scientific Issues.

### 3 Three conference calls with stakeholders were held to solicit feedback on the consolidated list of research gap areas and discuss criteria for prioritization

Preparatory materials, including a 2-page Stakeholder Call Information document (Appendix D), the list of Rotator Cuff Research Knowledge Gaps from the original report augmented by the Minnesota EPC researchers (Appendix C), the Executive Summary from the rotator cuff systematic review, Appendix B Table 1, a list of AHRQ’s Topic Selection Criteria (Appendix E), and an agenda were distributed to all 12 stakeholders prior to the conference calls. Ten stakeholders, representing most major types of stakeholders were available and participated in the conference calls. The calls were convened by the Minnesota EPC and ranged from 40–60 minutes in length. A separate call was held for three consumer representatives. One consumer also participated in a provider/researcher/funder call. Information from the conference calls was used to edit the list of research knowledge gaps and generate the Revised Rotator Cuff Research Gaps list below. A summary of the call (Appendix F) was sent out to all 12 stakeholders for comment along with the list of Revised Rotator Cuff Research Knowledge Gaps (Appendix G). Only minor additions were made to the list of research gaps during the conference calls; stakeholders indicated that the original gap list was comprehensive. Three items that require consensus but did not fit under methodological or scientific issues exclusively follow the gaps list:

### 4 Stakeholders’ comments and the Revised Rotator Cuff Research Gaps list were used to develop a two-part prioritization activity for stakeholders to rate and rank unresolved rotator cuff research areas: (1) rotator cuff methods issues and (2), unresolved scientific questions in rotator cuff treatment

We conducted a prioritization activity with 10 of the stakeholders, nine nongovernmental responders and one government employee, using web-based ranking software developed by RTI. Two consumer stakeholders were not invited to participate in the prioritization activity. Stakeholders were asked to prioritize methods related issues separate from scientific research topics. All stakeholders were provided six stars with which to indicate high priority methods issues and nine stars for scientific topics. A stakeholder could assign up to three stars for an issue or item if the stakeholder deemed it highly important.

An initial email invitation with links to the web-based software and instructions to complete the prioritization exercise was sent December 6, 2011, to all 10 stakeholders. A general reminder email with instructions was sent to all stakeholders on December 13, 2011. Personal emails asking the stakeholder to complete the exercise were sent to nonresponders December 20, 2011, and January 3, 2012. All invited stakeholders completed the exercise, a 100 percent participation rate.

### 5 Activity results were tabulated

Prioritization activity results were tabulated and rank was calculated based on 3^rd^ quartile scores. Scores were calculated as both weighted and nonweighted scores. Weighted scores totaled the number of stars stakeholders assigned to an individual issue or question. Unweighted scores totaled the number of stakeholders who voted for an individual issue or question. Weighted scores were also calculated by stakeholder category. Stakeholders were assigned to an MD researcher/clinician (three stakeholders), Physical Therapy/Massage Therapy researcher/clinician (three stakeholders), or Non-provider (four stakeholders comprised of medical directors, a funder, and a consumer). Ties in rankings were allowed. Appendix B Tables 2 and 3 provide ranking calculation detailed results.

Appendix B Table 1 Rotator cuff research gaps by Key Question and list of recent studies: for stakeholder conference call discussions

Appendix B Table 2 Stakeholder ranking of methods issues

Appendix B Table 3 Stakeholder ranking of scientific questions