# Search Strategy for Recently Published and Ongoing Studies

Medline was searched from September 16, 2009, through August 11, 2011, for randomized clinical trials and observational studies with comparison groups to determine if publications subsequent to the 2010 Alberta EPC systematic review partially filled the previously-identified knowledge gaps. The search strategy used in the original report was replicated. The search included a list of terms intended to identify all research publications associated with rotator cuff tears in adults. Searches for trials were further limited by terms to identify types of interventions that included a comparison group or included the term minimally-important clinical difference (MCID). Publications were assessed for relevance at the title and abstract level; applicable studies were retrieved, reviewed, and matched to one or more existing rotator cuff research gap areas.

We searched ClinicalTrials.gov (clinicaltrials.gov) for relevant ongoing studies. Searches were conducted using simple search terms such as “rotator cuff tear.” Trial records were reviewed for relevance based on the patient population of adults with acute or chronic partial- or full-thickness rotator cuff tears. Applicable studies were reviewed and matched to one or more existing research gap area.

Search Algorithm

Ovid Technologies, Inc. Email Service

Search for: limit 55 to yr=“2009 – 2011” Results: 500

Database: Ovid MEDLINE(R) 1948 to Present with Daily Update Search Strategy:

1. Rotator Cuff/ (3637)
2. ((rotator cuff* or rotator interval* or supraspin?tus or infraspin?tus or infraspin?teres minor or subscapularis or anterosuperior or posterosuperior) adj5 (tear or tears or tore or torn or lesion* or rupture* or avuls* or injur* or repair* or debride*)).mp. (3573)
3. exp tendon injuries/ (11739)
4. exp muscles/ (517043)
5. ((tendon or tendons or muscle* or muscular) adj5 (tear or tears or tore or torn or lesion* or rupture* or avuls* or injur* or repair* or debrid*)).mp. (24472)
6. ((ful or partial) adj4 (thick$ or tear or tears)).ti,ab. (2755)
7. 3 or 4 or 5 or 6 (536343)
8. exp shoulder/ or exp shoulder joint/ (19030)
9. (shoulder or glenohumeral).mp. (39003)
10. (rotator cuff* or rotator interval* or supraspin?tus or infraspin?tus or infraspin?teres minor or subscapularis or anterosuperior or posterosuperior).mp. (7496)
11. 8 or 9 or 10 (41011)
12. 7 and 11 (9334)
13. 1 or 2 or 12 (9930)
14. 1 and 2 and 12 (2392)
15. randomized controlled trial.pt. (302309)
16. controlled clinical trial.pt. (82015)
17. exp randomized controlled trials/ (71901)
18. exp Random Allocation/ (70749)
19. exp double-blind method/ (108914)
20. exp single-blind method/ (14735)
21. clinical trial.pt. (460613)
22. (clin$ adj25 (trial$ or study or studies or design)).ti,ab. (620304)
23. ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab. (109597)
24. exp placebos/ (29389)
25. placebo$.ti,ab. (127069)
26. random$.ti,ab. (507709)
27. exp research design/ (280789)
28. comparative study/ (1511948)
29. exp evaluation studies/ (146445)
30. exp follow-up studies/ (417212)
31. ((follow$ or observational or compar$) adj3 (trial$ or study or studies or design)).ti,ab. (310637)
32. exp prospective studies/ (291499)
33. exp epidemiologic studies/ (1289235)
34. exp causality/ (447500)
35. epidemiological factors.mp. (650)
36. (effect$ or outcome$ or allocat$ or control$ or assign$ or compar$ or experiment$ or analys$ or analyz$).mp. (8946248)
37. ((control$ or prospectiv$ or volunteer$ or participant$) adj5 (trial$ or study or studies or design)).mp. (989709)
38. (group or groups).ti,ab. (1863175)
39. cohort$.ti,ab. (167826)
40. case-control$.ti,ab. (55206)
41. cross sectional.ti,ab. (105853)
42. (case adj (comparison or referent$ or series)).ti,ab. (22211)
43. longitudinal.ti,ab. (98145)
44. (causation or causal$).ti,ab. (52896)
45. (analytic adj (study or studies)).mp. (1362)
46. single subject.ti,ab. (1502)
47. ssrd.ti,ab. (8)
48. n of 1.ti,ab. (33152)
49. baseline.ti,ab. (231517)
50. before after.ti,ab. (1886)
51. 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 (9910805)
52. animals/ not humans/ (3472944)
53. 51 not 52 (7525614)
54. 13 and 53 (6253)
55. limit 54 to (“all adult (19 plus years)” or “adult (19 to 44 years)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”) (4789)
56. limit 55 to yr=“2009 – 2011” (772)
57. 14 and 53 (1753)
58. limit 57 to (“all adult (19 plus years)” or “adult (19 to 44 years)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”) (1385)
59. limit 58 to yr=“2009 – 2011” (265)
60. 59 not 56 (0)
61. 56 not 59 (507)