# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
EPC: Evidence-based Practice Center
KQ: Key Question
RCT: Randomized controlled trials