# Results

## Research Needs

### Prioritization Results

Discussions with stakeholders revealed their deep concern that the lack of basic understanding of RLS and how it works greatly impedes the potential for forward movement of comparative effectiveness research in the field. Therefore a number of questions were added to the prioritization process that may be outside of the scope of the original CER, but that stakeholders felt were important earlier steps that would improve the ability to design and conduct research that will ultimately answer who would benefit from what RLS treatments. We analyzed weighted rankings for stakeholders participating in the Web-based prioritization process. From the seven stakeholders invited to rank research questions, six (86 percent) ranked both methodological and topical questions. We describe separately research needs that were within and outside the original CER scope.

Stakeholders separately ranked methodological and topical research questions (with no consideration of scope). A total of six of the seven stakeholders invited to participate in the ranking process ranked methodological and topical research questions. Participating stakeholders primarily identified themselves as physicians. We analyzed weighted stakeholder rankings for each research question to identify natural breakpoints (Table 1). High- and moderate-priority methodological research questions and high-priority topical research questions were deemed research needs.

Table 1 Stakeholder prioritization of research gap questions

Research Gap Questions
Ranking | Total (Points) | PICOTS Element
Methodological Topics Needing Consensus (n=5)
Tier 1: High Priority
What are the minimum important differences: (a) What IRLS scale score changes translate to clinically meaningful improvement for individual patients?; (b) Is there a correlation between change in IRLS and clinically important change in Clinical Global Impression?; (c) What is the correlation of polysomnography outcomes to remission of symptoms?; (d) What are the minimum outcomes to be reported? (e) What are the proportions of patients with remission of symptoms (IRLS score = 0), patient reported sleep outcomes, quality of life, etc.? | 8 | C,O
What is the sensitivity/specificity of RLS diagnostic tools? | 7 | I
Tier 2: Moderate Priority
What are the long-term consequences of RLS beyond currently understood sensory problems? | 5 | T
What time frames should be studied to establish treatment benefits and harms? | 4 | T
Tier 3: Low Priority
What is the causal pathway between RLS and insomnia? | 2 | O
Topical Questions Needing Trials (n=15)
Tier 1: High Priority
What are the genetic linkages and biomarkers that are associative or diagnostic or causally define RLS? | 17 | P
What environmental factors are associated with RLS? Is there a geographic/environmental predictor? | 12 | P
What is the short- and long-term comparative effectiveness and harms of treatments for RLS? | 12 | C,T
Is RLS a risk factor for cardiovascular disease and other health conditions? | 12 | O
Does tolerance/effectiveness of treatment for RLS vary by demographic/clinical/genetic factors? | 11 | P
Tier 2: Moderate Priority
What is the effect of RLS-related chronic sleep deprivation on cardiovascular health? | 10 | O
How might the progression of RLS be delayed? | 6 | O
What is the effectiveness of nonpharmacologic therapies for RLS? (mind-body, herbs/natural products, energy fields, and manipulation). | 5 | I
Are certain patient characteristics (iron deficiency or disease duration or severity more highly associated with augmentation with dopaminergic therapy? | 4 | P
Tier 3: Low Priority
What is the long-term effectiveness/comparative effectiveness of alpha 2 ligands for the treatment of RLS? | 3 | I
Does treatment of RLS improve non-RLS comorbidities? | 3 | O
What is the effectiveness of other drugs that are not dopamine agonists or alpha 2 ligands (e.g., opioids and sedative hypnotics)? | 2 | I
Does treatment efficacy differ by RLS symptom severity? | 2 | I,O
What is the effectiveness of approved RLS drugs on patient subgroups such as children, older adults, and individuals with secondary RLS? | 1 | P
How do the findings from published randomized trials apply to patients diagnosed in primary care settings and/or with milder disease of shorter duration? | 0 | I,C

Abbreviations: PICOTS = population, intervention, comparison, outcome, timing, setting; RLS = restless legs syndrome.

Note: Stakeholder rankings were weighted according to their assigned numerical ranking. For the methodological questions, if a stakeholder assigned a question the number one ranking, that question received three points; number two ranking – two points; number three ranking – one point. For the topical questions, if a stakeholder assigned a question the number one ranking, that question received five points; number two ranking – four points; number three ranking – three points; number four ranking – two points; number five ranking – one point.

## Methodological Research Needs

From among the methodological questions, stakeholders prioritized the identification of minimum important differences (within the scope of the CER) (with 50 percent of voters ranking it a priority) as well as the determination of the sensitivity/specificity of RLS diagnostic tools (outside of the scope of the CER) (Tier 1: High Priority), with 50 and 67 percent of stakeholders ranking them a priority respectively. The rankings of two additional methodological research gap questions were clustered together, but distantly less important to stakeholders than the top tier (Tier 2: Moderate Priority). Addressing methodological research needs will enhance the utility and translation of current and future research on treatments for RLS.

Within Scope:

- What are the minimum important differences in RLS outcome measures? Specifically
  ○ What IRLS scale scores (or changes in scores) translate to clinically meaningful improvement to assess for treatment effectiveness?
  ○ Is there a correlation between change in IRLS scale scores and clinically important change in Clinical Global Impression-if so what are those values?
  ○ What is the correlation of polysomnography outcomes to remission of symptoms?
  ○ What are the minimum outcomes to be reported?
  ○ What are the proportions of patients with remission of symptoms (IRLS score = 0), patient-reported sleep outcomes, quality of life, etc.?

Outside of Scope:

- What is the sensitivity and specificity of RLS diagnostic tools?

Methodological research needs pertain to how effectiveness is measured and the consistency and completeness of research studies and reporting on treatments for RLS.

### Considerations for Potential Research Designs

Methodological research needs could be addressed through a consensus development process (i.e., consensus conference), additional systematic reviews, epidemiological studies, and/or qualitative research.

## Topical Research Needs

A natural breakpoint in weighted rankings of topical research questions revealed five research needs, two within the scope of the original CER and three outside of it. All topical research needs addressed the PICOTS elements of populations and interventions. Addressing identified topical research needs will enhance understanding of efficacy and comparative effectiveness, which was limited in the draft CER.

Within Scope:

- What are the short- and long-term comparative effectiveness and harms of treatments for RLS?
- Does tolerance/effectiveness of treatment for RLS vary by demographic/clinical/genetic factors?

Outside of Scope:

- What environmental factors are associated with RLS?
  ○ Is there a geographic/environmental predictor?
- What genetic linkages and biomarkers are associated with, diagnostic of, or causally linked to RLS?
- Is RLS associated with cardiovascular disease and other health conditions—in particular what is the effect of RLS-related chronic sleep deprivation on cardiovascular health?

The draft CER, other reviews on the topic, current efficacy studies, and stakeholder discussions emphasized the need to address efficacy and comparative effectiveness for particular types of patients. While specific subgroups and interventions were not specified in this research need, subgroups can likely be defined by prevalent patient characteristics such as degree of symptoms, severity of disease, age, obesity, and other characteristics that appear to have an effect on response to treatment.

### Considerations for Potential Research Designs

Topical research needs would be best addressed with experimental designs (new randomized controlled trials for effectiveness and comparative effectiveness). However, identifying specific RLS patient subgroups based on environmental or genetic factors, or biomarkers (hypothesis generating research) may first be accomplished with less rigorous research designs. Observational studies and administrative databases could be used to extract hypothesized relationships between patient subgroups based on clinical characteristics, environmental factors and biomarkers and specific therapies or multimodal treatments. Garnering expert opinion regarding which RLS patient subgroups may respond differently to specific therapies should also be considered to create hypotheses. A similar process could be used to identify specific intervention characteristics of RLS patients that contribute to effectiveness. Furthermore, assessing environmental and genetic linkages is more efficiently accomplished through case-control studies of individuals with RLS (primary or secondary) and appropriately matched controls without RLS.

Once specific hypotheses are developed, they can be tested with experimental studies. Randomized Controlled Trials (RCTs) are likely the best approach to comparing interventions. RCTs with sufficient sample sizes can detect meaningful differences in outcomes because randomization minimizes bias from both observed and unobserved (or unmeasured) variables, giving a clear picture of treatment effects in specific populations. Sample size calculations should insure adequate power to test hypotheses and take any planned subgroup analyses into account. If sufficient subgroup sizes are not likely to be recruited, researchers may need to consider stratified recruitment from these populations. RCTs are the research design most likely to produce valid conclusions about the efficacy or comparative effectiveness of treatments. However, because they evaluate interventions in controlled settings within defined patient groups, they do not always resemble real-world patients and settings.

Cohort studies are less resource intensive, easier to recruit patients to, and provide results with greater applicability than RCTs. Prospective cohort studies enroll and follow patients over time to assess outcomes. The advantages of cohort studies include having a comparison group without randomizing patients and having a sufficient number and variety of patients. This study design makes testing for subgroup effects more feasible given the greater variety of patient and condition characteristics (age, gender, comorbidities, etc.) and the larger sample sizes that are typically possible with cohort studies. Because prospective cohort studies can better study real-world practice as compared with RCTs, many different variations in intervention characteristics can be studied as long as the appropriate data is collected and sufficient samples of patients receiving particular intervention variations. As mentioned above, case-control studies of individuals with RLS (primary or secondary) and appropriately matched controls without RLS would be a preferred study design to assess environmental and genetic linkages.

Following patients over time and attrition is burdensome in cohort studies, as in RCTs, especially when long followup periods are required. However, the greatest disadvantage with cohort studies is the potential selection bias created by nonrandomization. Controlling for the effects of all known and unknown confounding variables is difficult to accomplish through matching and/or statistical techniques. These confounding variables may account for the specific treatments received and therefore also be responsible for differences in outcomes, rather than the treatments themselves. Because treatment selection biases can come from patient and provider factors, these need to be identified, measured, and adjusted for use in statistical analyses.

Tables 2 through 6 provide details on design considerations for each identified research need.

#### Potential Research Design Considerations for Questions Inside Scope

Table 2 Design considerations: What are the short- and long-term comparative effectiveness and harms of treatments for RLS?

Considerations | RCT | Prospective Observational Study
Design description | Individual patients randomly assigned to treatment programs. | Individuals select treatment program.
Population | Patients diagnosed with RLS. | Patients diagnosed with RLS.
Intervention | RLS treatment, including both drug therapies and nondrug therapies. | RLS treatment, including both drug therapies and nondrug therapies.
Comparator | Nontreatment, drugs, or nondrug therapies. | Nontreatment, drugs, or nondrug therapies.
Outcomes | Symptom abatement (remission), decreased IRLS scores, clinical responders on IRLS scale scores, CGI, measures of sleep quality and treatment satisfaction, adherence, tolerance, reported AEs or SAEs. | Symptom abatement (remission), decreased IRLS scores, clinical responders on IRLS scale scores, CGI, measures of sleep quality and treatment satisfaction, adherence, tolerance, reported AEs or SAEs.
Timing | For at least 6–12 months?
Setting | Out-patient sleep medicine or neurology clinics. | Out-patient sleep medicine or neurology clinics.
Advantages for producing a valid result | This design, if feasible, will likely produce more valid results. | This design is more feasible than an RCT but will subject to confounding. Investigators should be careful to collect data necessary to control for known effect modifiers and confounders.
Resource use, size, and duration | RCTs are difficult to recruit to, require large sample sizes and are challenged by loss-to-follow-up. | Sample sizes will need to be large, and lost-to-follow-up issues will likely be significant.
Ethical, legal, and social issues | No ethical, legal or social issues exist. | No ethical, legal or social issues exist.
Availability of data/ability to recruit | Poor. RCTs require significant time commitment; patients may be unwilling to leave treatment choice to randomization. | Fewer challenges to recruitment than with RCT.

Abbreviations: AE = adverse event; CGI = Clinical Global Impression; IRLS = International RLS Study Group; RCT = randomized controlled trial; RLS = restless legs syndrome; SAEs = serious adverse events.

Table 3 Design considerations: Does tolerance/effectiveness of treatment for RLS vary by demographic/clinical/genetic factors?

Considerations | Meta-Analysis of Published Data or Individual Participant Data | Prospective Observational Study
Design description | Systematic review of future published literature that seeks to determine if tolerance/effectiveness of treatment for RLS vary by demographic/clinical/genetic factors. Individual patient level meta-analysis or subgroup reporting from existing studies that includes key baseline demographic/clinical/genetic factors. | Prospective observational studies or post RCT open label continuation studies that assess long-term tolerance and effectiveness according to key demographic, clinical and genetic factors.
Population | Patients diagnosed with RLS receiving treatment. | Patients diagnosed with RLS receiving treatment.
Intervention | Treatment for RLS. (Both drug and nondrug treatment options could be considered.) | Treatment for RLS. (Both drug and nondrug treatment options could be considered.)
Comparator | Individuals with RLS. | Individuals with RLS.
Outcomes | Measures of drug tolerance and effectiveness according to baseline demographic/clinical and genetic factors including primary vs. secondary RLS. Outcomes would include: adherence, augmentation, treatment-related symptom. abatement, decreased IRLS scale scores, reported AEs or SAEs. | Baseline demographic information including clinical and genetic factors as well as treatment-related symptom abatement, decreased IRLS scores, reported AEs or SAEs.
Timing | At least 12 months. | At least 12 months.
Setting | Primary care clinics, Out-patient sleep medicine or neurology clinic. | Out-patient sleep medicine or neurology clinic.
Advantages for producing a valid result | Benefits of a potentially large sample size, no recruitment necessary with the disadvantages of pooling potentially varying patient populations. | This design is very feasible as treatment decision is determined by patient and provider, not by randomization.
Resource use, size, and duration | Resource use is less than an RCT or even an Observational study but would still require investigator and analysis time. | Resource use is likely higher than an meta-analysis but still smaller than a large full scale long-term RCT.
Ethical, legal, and social issues | No important ethical, legal or social issues. | No important ethical, legal or social issues.
Availability of data/ability to recruit | Fair. | Fair.

Abbreviations: AE = adverse event; IRLS = International RLS Study Group; RCT = randomized controlled trial; RLS = restless legs syndrome; SAEs = serious adverse events.

#### Potential Research Design Considerations for Questions Outside Scope

Table 4 Design considerations: What geographic/environmental factors are associated with RLS?

Considerations | Meta-Analysis of Existing Published Data and/or Prospective Observational Studies
Design description | Systematic review of the literature that seeks to determine if there are geographic or environmental factors similar across RLS populations. Population based studies to assess geographic and environmental factors at baseline and risk of development of RLS (prospective cohort and/or case-control studies).
Population | Patients with RLS (primary and secondary).
Intervention | RLS diagnosis.
Comparator | Matched controls (age, gender, race, comorbid conditions, socio-economic status etc.).
Outcomes | Odds ratios for RLS vs. controls associated with putative geographic, environmental factors.
Timing | NA
Setting | Population based.
Advantages for producing a valid result | Results will attempt to determine the existence of geographic or environmental factors that may be associated with either primary or secondary RLS.
Resource use, size, and duration | Modest: study might be able to be conducted using secondary data analysis of existing population based studies of individuals with and without RLS. Resource use includes significant investigator and analyst time and may require additional survey and data collection from existing cohorts.
Ethical, legal, and social issues | Little important ethical, legal, or social issues exist.
Availability of data/ability to recruit | Unknown, data will be limited to those studies that include demographic outcomes.

Abbreviations: NA = not available; RLS = restless legs syndrome.

Table 5 Design considerations: What genetic linkages/biomarkers are associative, diagnostic of, or causally define RLS?

Considerations | Meta-Analysis of Existing Data | Observational Study
Design description | Systematic review of the literature that seeks to determine if there are genetic linkages and biomarkers that are associative, diagnostic of, or causally define RLS. | Case-control studies of individuals diagnosed with RLS compared with appropriately matched controls (age, gender, comorbid conditions) would be enrolled regardless of treatment intentions. Studies should separately address individuals with primary and secondary RLS.
Population | Studies of RLS patients with baseline demographic data that include genetic and biomarker information. | Patients with an RLS diagnosis (primary and secondary).
Intervention | RLS diagnosis. | RLS diagnosis.
Comparator | Matched controls (age, gender, race, comorbidities. | Matched controls (e.g. age, gender, race, comorbidities).
Outcomes | Baseline demographic data to include genetic and biomarker information. | Genetic and biomarker information.
Timing | NA | NA
Setting | Population based studies, primary care or out-patient sleep medicine or neurology clinic. | Population based studies, primary care or out-patient sleep medicine or neurology clinic.
Advantages for producing a valid result | Results will attempt to determine the existence of genetic and biomarker predictors for RLS. | This design is very feasible as treatment decision is determined by patient and provider, not by randomization. Causality will be difficult to determine, but it is possible that associations between genetics and RLS diagnosis will be able to be seen with sufficient population size.
Resource use, size, and duration | Minimal, study can be conducted by secondary data analysis. Resource use includes significant investigator and analyst time. | Sample size will need to be large given the number of treatment options available. Pharmacoepidemiologic datasets may be of use to more efficiently address this.
Ethical, legal, and social issues | No important ethical, legal or social issues exist. | No important ethical, legal or social issues exist.
Availability of data/ability to recruit | Unknown, data will be limited to those studies that include genetic and biomarker outcomes. | Modest challenges to recruitment.

Abbreviations: NA = not available; RLS = restless legs syndrome.

Table 6 Design considerations: Is RLS a risk factor for cardiovascular disease and other health conditions/outcomes?

Considerations | Meta-Analysis of Individual Participant Data
Design description | Systematic review of the literature that seeks to determine if RLS is an independent risk factor for cardiovascular disease and other health conditions.
Population | Patients diagnosed with RLS.
Intervention | RLS diagnosis.
Comparator | Matched controls without RLS.
Outcomes | Cardiovascular disease and other health conditions of key interest (depression, motor vehicle accidents, worker productivity).
Timing | Prospective (years).
Setting | Primary care, population studies, out-patient sleep medicine or neurology clinics.
Advantages for producing a valid result | This design is easily done but results will depend on the quality of available studies and the outcomes reported.
Resource use, size, and duration | This design is the most feasible but will require some investigator and analyst investment.
Ethical, legal, and social issues | No ethical, legal or social issues exist.
Availability of data/ability to recruit | Good.

Abbreviation: RLS = restless legs syndrome.