# References

1 Wilt TJ, MacDonald R, Ouellette J, et al. Treatment for Restless Legs Syndrome. Comparative Effectiveness Review No. 86. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.) AHRQ Publication No. 12(13)-EHC147-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Walters AS. Toward a better definition of the restless legs syndrome. The International Restless Legs Syndrome Study Group. Mov Disord. Sep. 1995;10(5):634-42. [pmid: 8552117].
3 Allen RP, Picchietti D, Hening WA, et al. Restless legs syndrome: diagnostic criteria, special considerations, and epidemiology A report from the restless legs syndrome diagnosis and epidemiology workshop at the National Institutes of Health. Sleep Med. Mar. 2003;4(2):101-19. [pmid: 14592341].
4 Trenkwalder C, Paulus W. Restless legs syndrome: pathophysiology, clinical presentation and management. Nat Rev Neurol. Jun. 2010;6(6):337-46. [pmid: 20531433].
5 Garcia-Borreguero D, Egatz R, Winkelmann J, et al. Epidemiology of restless legs syndrome: the current status. Sleep Med Rev. Jun. 2006;10(3):153-67. [pmid: 16762806].
6 Silber MH, Ehrenberg BL, Allen RP, et al. An algorithm for the management of restless legs syndrome. Mayo Clin Proc. Jul. 2004;79(7):916-22. [pmid: 15244390].
7 Garcia-Borreguero D, Williams AM. Dopaminergic augmentation of restless legs syndrome. Sleep Med Rev. Oct. 2010;14(5):339-46. [pmid: 20219397].
8 Cesnik E, Casetta I, Turri M, et al. Transient RLS during pregnancy is a risk factor for the chronic idiopathic form. Neurology. Dec. 7. 2010;75(23):2117-20. [pmid: 21135386].
9 Manconi M, Govoni V, De Vito A, et al. Restless legs syndrome and pregnancy. Neurology. Sep. 28. 2004;63(6):1065-9. [pmid: 15452299].
10 O’Haire C, McPheeters M, Nakamoto EK, et al. Methods for Engaging Stakeholders to Identify and Prioritize Future Research Needs. Methods Future Research Needs Report No. 4. (Prepared by the Oregon Evidence-based Practice Center and the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 11-EHC044-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
11 Andrews J. Prioritization Criteria Methodology for Future Research Needs Proposals Within the Effective Health Care Program. Methods Future Research Needs Report No. 10. (Prepared by Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.) AHRQ Publication No. 12(13)-EHC152-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
12 SurveyMonkey. 2012. www.surveymonkey.com.