# Methods

We used a deliberative process to identify and prioritize research questions relevant to the evidence gaps identified in the recently completed draft CER on treatments for RLS.1 Figure 2 illustrates the eight steps used to accomplish the objectives of this project.

Figure 2 Project flow

Abbreviations: CER = Comparative Effectiveness Review; PICOTS = population, intervention, comparison, outcome, timing, setting.

Figure 2 is the literature flow diagram. It describes the literature search and screen processes which is also described in the report text.

## Engagement of Stakeholders

We recruited a diverse panel of stakeholders with varied perspectives relevant to the topic. We followed guidance on stakeholder engagement for recruitment and communication.10 We sought to recruit stakeholders who were actively interested in treatments for patients with RLS who wished to help shape future research priorities. We identified potential stakeholders via several means. We sought recommendations from the CER project team, including select Key Informants and Technical Expert Panel members. We also identified stakeholders who were serving on panels from related Agency for Healthcare Research and Quality (AHRQ) FRNs projects or who were listed in the Effective Health Care Contacts Database.11 Research representatives were national experts familiar with evidence-based medicine and aware of the obstacles faced in conducting well-designed research from neurology, psychology, and sleep medicine. Many stakeholders were also involved in the CER process as Key Informants, Technical Expert Panel members, or peer reviewers.

### Handling Conflicts of Interest

We collected disclosures of conflicts of interests from all stakeholders. Disclosed interests did not bar any stakeholders from participation, but allowed the Evidence-based Practice Center (EPC) to evaluate contributions based upon possible conflicts. Stakeholders used a Web-based survey to rank specific topical research questions during the prioritization exercise, thus researchers and funders were blind to the stated opinions of one another.

### Refinement of Research Questions

We provided members of our stakeholder panel with a preliminary set of research questions prior to our conference call. During the conference calls, we sought stakeholder input to further refine the research questions (i.e., organization and wording of the questions, identification of additional research questions, and elimination of research questions with limited clinical value). To facilitate this input, we provided stakeholders in advance with background material including the draft CER executive summary and the Effective Health Care Program Selection Criteria. We conducted several conference calls with available stakeholders in June of 2012. A total of seven stakeholders participated in the calls. All participants provided input on the calls. We circulated summaries of group calls to all participants. We invited stakeholders to clarify or supplement the call summaries or to suggest additional research questions in response to the call summaries, and several did so via email. We revised the preliminary questions based upon these discussions and email communications. The revised set of research questions for prioritization appears in Appendix A.

### Prioritization

Our stakeholders were asked to prioritize these research questions according to specified criteria based on the potential impact of future research on that question. These criteria have been operationalized into seven components specific to EPC FRN projects. These components, called “Potential Value Criteria,”11 are as follows:

- Potential for significant health impact on the current and future health status of people with respect to burden of the disease and health outcomes: mortality, morbidity and quality of life.
- Potential to reduce important inappropriate (or unexplained) variation in clinical practices known to relate to quality of care. Potential to resolve controversy or dilemmas in what constitutes appropriate health care. Potential to improve decisionmaking for patient or provider, by decreasing uncertainty.
- Potential for significant (nontrivial) economic impact related to the costs of health service: to reduce unnecessary or excessive costs; to reduce high costs due to high volume use; to reduce high costs due to high unit cost or aggregate cost. Costs may impact consumers, patients, health care systems, or payers.
- Potential risk from inaction: Unintended harms from lack of prioritization of proposed research; opportunity cost of inaction.
- Addresses inequities, vulnerable, diverse populations (including issues for patient subgroups); potential to reduce health inequities.
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition.
- Potential for new knowledge: research would not be redundant; question not sufficiently researched, including completed and in-process research; utility of available evidence limited by changes in practice, e.g., disease detection or evolution in technology.

We then asked stakeholders to rank the research questions focusing on the Potential Impact criteria (i.e., the likelihood that addressing the research gap question would inform clinical practice and policy). We developed a Web-based survey using SurveyMonkey to collect stakeholder prioritization of the research gap questions.12 All seven stakeholders were invited to rank research questions identified via the stakeholder conference calls. These stakeholders were asked to numerically rank their top three of six methodological research questions, and their top five of 14 topical research questions.

Stakeholder rankings were weighted according to their assigned numerical ranking. For the methodological questions, if a stakeholder assigned a question the number one ranking, that question received three points; number two ranking—two points; number three ranking—one point. For the topical questions, if a stakeholder assigned a question the number one ranking, that question received five points; number two ranking—four points; number three ranking—three points; number four ranking—two points; number five ranking—one point. We identified natural breakpoints in the weighted rankings that separated high-, moderate-, and low-priority research questions. Highly prioritized research questions were considered research needs. We disseminated results of the forced ranking procedure to all engaged stakeholders for review and comment prior to preparing the final report.

We then evaluated the feasibility criteria for research needs. We framed feasibility in terms of anticipated research designs. For example, factors that affect the feasibility of conducting randomized controlled trials include the sample size needed for the outcome, the size of the available pool of potential subjects, followup duration, willingness to randomize, and applicability issues. In contrast to randomization and applicability, observational studies face feasibility issues related to measuring study variables using different data sources and unobserved variables that create risk of bias.

## Research Design Considerations

We generated research design considerations for identified research needs. For methodological research needs, we provided context and described resources and research design considerations potentially useful to researchers, facilitators, and funders of this type of research. For topical research needs, we highlighted the relevant PICOTS (population, intervention, comparison, outcome, timing, setting) element(s), provided context, described related ongoing research, and discussed potential research designs. Because more than one research design can be applied to an individual research need, we discussed the advantages and disadvantages of different options. We did not consult with stakeholders for input on research design considerations.