# Executive Summary

## Background

This Future Research Needs (FRN) project is a followup to the draft Comparative Effectiveness Review (CER), “Treatment for Restless Legs Syndrome.” The review was motivated by uncertainty around the effectiveness and comparative effectiveness of treatments for restless legs syndrome (RLS). The purpose of this FRN project is to identify and prioritize specific gaps in the current literature about the effectiveness and comparative effectiveness of treatments for RLS for which additional research would aid decisionmakers.

We used a deliberative process to identify evidence gaps, translate gaps into researchable questions, and solicit stakeholder opinion on the importance of research questions. This report proposes specific research needs along with research design considerations that may be useful in advancing the field.

The analytic framework adapted from the original draft CER (Figure A) describes the focus of the review. Research evaluated Key Questions (KQs) regarding treatment effectiveness and comparative effectiveness (KQ 1), long-term treatment tolerability, sustainability, and harms (KQ 2). We also assessed the impact of patient characteristics on the benefits and harms of treatment for RLS (KQ 3).1

Figure A Analytic framework

Abbreviations: KQ = Key Question; RLS = restless legs syndrome.

Note: KQ 1: What is the comparative effectiveness of treatments for RLS?

KQ 2: What are the harms of RLS treatments?

KQ 3: What is the effect of patient characteristics on the benefits and harms of treatment for RLS?

Figure A depicts how treatments for RLS (KQ1) may contribute to health outcomes in the target population in light of potential modifiers of effect (KQ3) such as age, gender, sex, RLS severity, etiology, comorbidities, iron status, pregnancy and end-stage renal disease. In general, the figure illustrates how treatments for RLS may result in primary outcomes such as change in disease severity and impact on function and secondary outcomes such as quality of life outcomes and patient-reported sleep outcomes. Also, adverse events may occur at any point after the treatment is received (KQ2).

The literature search conducted for the CER covered the bibliographic databases MEDLINE (via OVID), Embase, and Natural Standards through September 17, 2011. Our intent was to identify and synthesize data from relevant comparative effectiveness research on treatments for RLS.

For KQ 1 (What is the comparative effectiveness of treatment for RLS) authors of the CER found that randomized controlled trial (RCT) results were limited to short-term (<6 months) efficacy studies of active drugs versus placebo or usual care. Overall high-strength evidence showed that compared with placebo, dopamine agonists (ropinirole, pramipexole, and rotigotine) reduced RLS symptoms, increased the percentage of patients with a clinically important response (defined as a ≥50 percent reduction in International Restless Legs Syndrome Study Group (IRLS) symptom scale scores or as a report of “improved” or “much improved” on patient or clinician-reported global impression scale) and improved disease-specific quality of life and patient-reported sleep outcomes. High-strength evidence showed that pregabalin increased the percentage of patients with a clinically important response (≥50 percent reduction in IRLS). Low-strength evidence demonstrated that calcium channel alpha-2-delta ligands improved clinician-reported global impression, disease-specific quality of life, and patient-reported sleep outcomes compared with placebo. Applicability was limited to nonpregnant, white, middle-aged adults with few comorbidities and RLS symptoms that were long term, frequent, and high-moderate to very severe.

As described in the full report, only three small RCTs addressed nonpharmacologic interventions. Pneumatic compression devices reduced IRLS symptom scale scores more than sham (moderate-strength evidence). Strength training and treadmill walking improved IRLS symptoms but adherence was poor and the study reported results only for completers. The botanical extract valerian was not effective. Evidence for both interventions was low strength.

No eligible studies assessed opioids, sedative hypnotics, or tramadol, though these are used for RLS treatment. One study found that the dopamine agonist cabergoline improved scores on the IRLS symptom scale and RLS quality of life scale more than levodopa (moderate-strength evidence). However, cabergoline is not approved for treatment of RLS and has limited use in the United States. Observational studies and long-term open-label followup from RCTs of pharmacologic interventions found that withdrawal from treatment at 1 year or more was common, ranging from 13 to 57 percent. Reasons for withdrawal included lack of efficacy (6 to 32 percent) and adverse events including augmentation (7 to 62 percent).

For KQ 2 (What are the harms of RLS treatments?), study withdrawals (due to any reason) from RCTs were slightly less common in patients randomized to dopaminergic agents than to placebo (moderate-strength evidence). Study withdrawals due to adverse effects were more common (though not statistically so) with dopamine agonist treatment than placebo (low-strength evidence). Differences were primarily due to an increase in withdrawals related to adverse effects (application site reactions) reported in three trials of transdermal rotigotine. More patients randomized to dopamine agonist had at least one adverse effect compared with placebo (high-strength evidence). Short-term adverse effects from treatment with dopamine agonists compared with placebo were nausea, vomiting, and somnolence (high-strength evidence for all these outcomes). Application site reactions were much more common with transdermal rotigotine than with placebo (high-strength evidence).

Some indirect evidence from placebo-controlled trials suggested that fatigue may be more common with ropinirole then pramipexole or rotigotine. Data from observation studies indicated that long-term augmentation ranged from 2.5 percent to 60 percent and varied markedly by type of dopamine agonist, followup time, study design, and method used to ascertain augmentation. No clear pattern explained this variability. Withdrawal from mostly dopamine agonist and levodopa treatment was common, occurring in 13 percent to 57 percent of subjects due either to lack of efficacy or adverse effects. Most studies reported treatment withdrawals greater than 20 percent at 1 year with adverse events including augmentation ranging from 7 to 62 percent.

For KQ 3 (What is the effect of patient characteristics on the benefits and harms of treatment for RLS?) the authors found that no RCTs examined the effect of patient or RLS characteristics on benefits and harms of treatments for primary RLS. No RCTs enrolled children or women who were pregnant or recently postpartum, and nearly all specifically excluded these individuals. No eligible studies enrolled individuals with end-stage renal disease, and almost all specifically excluded these individuals. Two small randomized trials of iron therapy versus placebo in adults with iron deficiency provided low-strength evidence that iron may improve IRLS symptom scale scores and possibly the percentage of adults considered IRLS responders

Nearly all of the pharmacologic trials (dopamine agonist, calcium channel alpha-2-delta ligands, and iron therapies) were considered of good quality (having a low risk of bias). The applicability of the included evidence for RLS treatments is limited. Included studies were mostly short-term, placebo-controlled efficacy studies of dopamine agonists and calcium channel alpha-2-delta ligands conducted in a highly selected population of adults with moderate to very severe primary RLS of long-duration. Applicability to adults with less frequent or less severe (mild to moderate) RLS symptoms, children, or those with secondary RLS is unknown. Furthermore, randomized trials did not address long-term effectiveness, the comparative effectiveness and harms of commonly used treatments, or the effect of patient or RLS characteristics on outcomes.

## Methods

We used a deliberative process to identify and prioritize research questions relevant to the evidence gaps identified in the CER. Figure B illustrates the eight steps used to accomplish the objectives of this project.

Figure B Project flow

Abbreviations: CER = Comparative Effectiveness Review; PICOTS = population, intervention, comparison, outcome, timing, setting.

Figure B is the literature flow diagram. It describes the literature search and screen processes which is also described in the report text..

First, research gaps identified in the CER were translated into research questions. Second, a diverse stakeholder panel with representation from various perspectives relevant to the topic was assembled. Research representatives were national experts familiar with evidence-based medicine and the obstacles faced in conducting well-designed research from the fields of neurology, psychology, and sleep medicine. Providers and consumers, including representation from the Restless Legs Syndrome Foundation, were also engaged because the decisional dilemmas faced by these groups are critical to identifying and prioritizing research questions.

We held a conference call with stakeholders to refine the original research gaps identified during the CER process. Based upon these conversations, we refined and added to our initial list of research gap questions. These are separated into categories (methodological research questions that need to be addressed to enhance the usefulness of current research, and topical research questions that have not been sufficiently addressed in the current literature). Because the stakeholders believed that some research questions that were considered out of scope from our review were critical to future comparative effectiveness research we elected to leave them in for prioritization processing. We sent the list of research questions to the stakeholders for ranking. Stakeholders numerically ranked their top three methodological research questions from a total of six and their top five topical research questions from a total of fourteen.

Rankings were weighted according to stakeholder numerical ordering of questions. Based on the natural breakpoints in these rankings, we determined high, moderate, and low priority research gap questions. High priority questions were deemed research needs. We then identified and discussed research design considerations for research needs.

## Results

### Prioritization Results

Discussions with stakeholders revealed their deep concern that the lack of basic understanding of RLS and how it works greatly impedes the potential for forward movement of research in the field. Therefore a number of questions were added to the prioritization process that are outside of the scope of the original CER, but that stakeholders felt were important earlier steps that would improve the ability to design and conduct research that will ultimately answer who would benefit from what RLS treatments. We analyzed weighted rankings for stakeholders participating in the Web-based prioritization process. From the seven stakeholders invited to rank research questions, six (86 percent) ranked both methodological and topical questions. We describe separately research needs that were within and outside the original CER scope.

#### Methodological Research Needs

Natural breakpoints in weighted rankings revealed two moderate-priority methodological research questions, one within the scope of the original CER and one outside of it. Because no methodological research question appeared to be of high priority, we considered the moderate-priority methodological research questions to be research needs. Addressing methodological research needs will improve the quality and enhance the clinical utility and translation of current and future research on treatments for RLS.

Within Scope:

- What are the minimum important differences in RLS outcome measures? Specifically
  ○ What IRLS scale scores (or changes in scores) translate to clinically meaningful improvement to assess for treatment effectiveness?
  ○ Is there a correlation between change in IRLS scale scores and clinically important change in Clinical Global Impression-if so what are those values?
  ○ What is the correlation of polysomnography outcomes to remission of symptoms?
  ○ What are the minimum outcomes to be reported?
  ○ What are the proportions of patients with remission of symptoms (IRLS score = 0), patient-reported sleep outcomes, quality of life, etc.?

Outside of Scope:

- What is the sensitivity and specificity of RLS diagnostic tools?

##### Considerations for Potential Research Designs

Methodological research needs could be addressed through a consensus development process (i.e., consensus conference), additional systematic reviews, epidemiological studies, diagnostic accuracy studies in targeted populations, and/or qualitative research.

#### Topical Research Needs

Topical research needs pertained to effectiveness and harms of treatments, clinical impact of RLS overall and in specific subgroups and areas to improve our understanding of RLS diagnosis and etiology. A natural breakpoint in weighted rankings of topical research questions revealed five research needs, two within the scope of the original CER and three outside of it. All topical research needs addressed the PICOTS (population, intervention, comparison, outcome, timing, setting) elements of populations and interventions. Addressing topical research needs will enhance understanding of efficacy and comparative effectiveness which was limited in the draft CER.

Within Scope:

- What are the short- and long-term comparative effectiveness and harms of treatments for RLS?
- Does tolerance/effectiveness of treatment for RLS vary by demographic/clinical/genetic factors?

Outside of Scope:

- What environmental factors are associated with RLS?
  ○ Is there a geographic/environmental predictor?
- What genetic linkages and biomarkers are associated with, diagnostic of, or causally linked to RLS?
- Is RLS associated with cardiovascular disease and other health conditions—in particular, what is the effect of RLS-related chronic sleep deprivation on cardiovascular health?

The draft CER, other reviews on the topic, current efficacy studies, and stakeholder discussions emphasized the need to address efficacy and comparative effectiveness for particular types of patients. While specific subgroups and interventions were not specified in this research need, subgroups can likely be defined by prevalent patient characteristics such as degree of symptoms, severity and etiology of disease, age, obesity, and other characteristics that appear to have an effect on response to treatment.

##### Considerations for Potential Research Designs

For each proposed research question, specific research designs are discussed in detail in the full text of this document. Some topical research needs are best addressed with experimental designs-randomized or controlled intervention trials. However, identifying specific patient subgroups whereby the effectiveness and harms of treatments may vary (hypothesis-generating research) may first be accomplished with less rigorous research designs (or from exploratory subgroup analyses in randomized trials). Additionally, understanding etiology, diagnostic criteria and prognosis is likely best first assessed by using high-quality prospective observational studies.

Observational studies and administrative databases could be used to extract hypothesized relationships between patient subgroups based on clinical characteristics, environmental factors and biomarkers and specific therapies or multimodal treatments. Hypotheses could be created through garnering expert opinion about which patient subgroups may respond differently to specific RLS therapies. However, this might be additionally addressed by evaluating subgroup findings from large randomized trials. A similar process could be used to identify specific intervention characteristics that contribute to effectiveness.

Once specific hypotheses are developed, they can be tested with experimental studies. RCTs are likely the best approach to comparing interventions. Sample size calculations should ensure adequate power to test selected predefined hypotheses and take any planned subgroup analyses into account. If sufficient subgroup sizes are not likely to be recruited, researchers may need to consider stratified recruitment to increase enrollment of these populations. Because RCTs often evaluate interventions in highly controlled settings within defined patient groups, they may not be fully applicable to broader populations seen in many (especially primary care) settings. Cohort studies and long-term extension of randomized trials would be of value in assessing long-term harms and treatment compliance particularly if including a broad spectrum of individuals and RLS severity.

## Discussion

This FRN project refined and prioritized research needs relevant to the KQs addressed in the draft CER, “Treatment for Restless Legs Syndrome.”1 Additionally, questions were proposed that while outside the scope of the current CER, were identified as gaps in the body of literature that Stakeholders felt impedes the field greatly. Therefore, multiple gaps in evidence were identified that required future research to improve delivery of health care for patients identified with RLS.

We conducted a deliberative process to refine and expand research gaps identified in the CER through conversations with stakeholders with various perspectives of expertise on the topic. This process identified six methodological and fourteen topical research questions thought to address identified evidence gaps. We then had stakeholders rank research questions. The highly ranked questions were deemed research needs. Stakeholders prioritized three methodological and five topical research needs.

Addressing methodological research needs will enhance the quality, clinical utility and comparability of future studies of RLS treatments. A common set of patient-centered and intermediate outcomes, with guidance on interpreting clinically important changes in outcomes scale scores will provide researchers with standardized and validated approaches to collecting outcomes data and determining effectiveness. Guidance on how RLS interventions should be defined in research studies and variables to report in studies as determined by a multidisciplinary panel will, when utilized, enhance the quality of research on the topic.

Advancement in the field needs to address which treatments for RLS are effective for which patients. In particular, our evidence report was intended to be a CER. Unfortunately, few studies directly compared treatments and indirect comparisons were not feasible due to differences in populations enrolled and the limited number of studies available. Additionally, a better understanding of the benefits and harms of treatment for RLS is essential to understanding their effectiveness. Testing specific hypothesis will fill specific evidence gaps identified and prioritized by our stakeholders.

While one strength of this project is the multidisciplinary perspective brought by broad stakeholder participation a larger sample of stakeholders would be useful. The stakeholders participating in this project represented various perspectives on treatments for RLS. However, the prioritized research needs reflect the opinions of these stakeholders and may not be generalizable to the population of stakeholders on this topic.

## Conclusions

Addressing research needs identified in this FRN project will help create a broader and stronger evidence base in which clinical decisions can be made. Future research addressing specific research questions is likely to establish a preliminary research agenda on this topic. The highest priority research needs, both within the scope of the original CER and outside if it are summarized below:

Within Scope:

- What are the minimum important differences in RLS outcome measures? Specifically:
  ○ What IRLS scale scores (or changes in scores) translate to clinically meaningful improvement to assess for treatment effectiveness?
  ○ Is there a correlation between change in IRLS scale scores and clinically important change in Clinical Global Impression-if so what are those values?
  ○ What is the correlation of polysomnography outcomes to remission of symptoms?
  ○ What are the minimum outcomes to be reported?
  ○ What are the proportions of patients with remission of symptoms (IRLS score = 0), patient reported sleep outcomes, quality of life, etc.?
- What are the short- and long-term comparative effectiveness and harms of treatments for RLS?
- Does tolerance/effectiveness of treatment for RLS vary by demographic/clinical/genetic factors?

Outside of Scope:

- What is the sensitivity and specificity of RLS diagnostic tools?
- What environmental factors are associated with RLS?
  ○ Is there a geographic/environmental predictor?
- What genetic linkages and biomarkers are associated with, diagnostic of, or causally linked to RLS?
- Is RLS associated with cardiovascular disease and other health conditions-in particular what is the effect of RLS-related chronic sleep deprivation on cardiovascular health?

## References

1 Wilt TJ, MacDonald R, Ouellette J, et al. Treatment for Restless Legs Syndrome. Comparative Effectiveness Review No. 86. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I) AHRQ Publication No. 12(13)-EHC147-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.