# Discussion

This FRN project refined and prioritized research needs relevant to the KQs addressed in the draft CER, “Treatment for Restless Legs Syndrome.”1 We conducted a deliberative process to refine and expand research gaps identified in the CER through conversations with stakeholders with various perspectives of expertise on the topic. This process identified six methodological and 14 topical research questions thought to address identified evidence gaps. We then had stakeholders rank research questions. The highly ranked questions were deemed research needs. Stakeholders prioritized two methodological and five topical research needs.

Addressing methodological research needs will enhance the utility and comparability of future studies of treatments for RLS. A common set of patient-centered and intermediate outcomes, with guidance on interpreting changes in outcomes scale scores, will provide researchers with concrete approaches to collecting outcomes data and determining effectiveness. Guidance on how RLS interventions should be defined in research studies and variables to report in studies as determined by a multidisciplinary panel will, when utilized, enhance the quality of research on the topic.

Advancement in the field needs to address which treatments for RLS are effective for which patients. Additionally, a better understanding of the benefits and harms of treatment for RLS is essential to understanding their effectiveness. Testing specific hypothesis will fill specific evidence gaps identified and prioritized by our stakeholders.

Although one strength of this project is the multidisciplinary perspective brought by broad stakeholder participation, our inability to collect a perspective from a larger sample of stakeholders is also a limitation. The stakeholders participating in this project represented various perspectives on treatments for RLS. However, the prioritized research needs reflect the opinions of these stakeholders and may not be generalizable to the population of stakeholders on this topic.