# Background

## Context

This Future Research Needs (FRN) project is a followup to the draft Comparative Effectiveness Review (CER), “Treatment for Restless Legs Syndrome.”1 The review was motivated by uncertainty around the effectiveness and comparative effectiveness of treatments for restless legs syndrome (RLS). FRN projects identify gaps in the current research that limit the conclusions in CERs and inform those who conduct and fund research of these gaps. FRN projects aim to encourage research likely to fill gaps and make the body of evidence more useful to decisionmakers. The report addressed the following Key Questions (KQs):

KQ 1 What is the comparative effectiveness of treatments for RLS?
  a. What are the benefits from RLS treatments when compared with placebo or no treatment?
  b. What are the benefits from RLS treatments when compared with other active treatments?
  c. What is the durability and sustainability of treatment benefits?
KQ 2 What are the harms from RLS treatments?
  a. What are the harms from RLS treatments when compared with placebo or no treatment?
  b. What are the harms from RLS treatments when compared with other active treatments?
  c. What are the long-term harms from treatment?
- KQ 3. What is the effect of patient characteristics on the benefits and harms of treatment for RLS?

## Restless Legs Syndrome

RLS is a neurological disorder characterized by unpleasant sensations in the legs and a distressing, irresistible urge to move them. The condition is defined and diagnosed based solely on clinical criteria. The essential diagnostic criteria for RLS were established by the International Restless Legs Syndrome Study Group (IRLS) in 1995^2^ and revised in 2003.^3^

RLS symptoms are triggered by rest or inactivity and worsen at night. Movement such as walking, stretching, or bending the legs provides partial or complete relief. Yet, relief is temporary, and symptoms return when movement ceases.4

RLS encompasses a wide spectrum of symptom severity and frequency. Mild RLS may result in only minor annoyance, but severe RLS can interfere with work or social activities and reduce function and emotional well-being. RLS-induced sleep disruption may lead to poor daytime functioning, anxiety, and depression. Sleep deprivation and daytime fatigue are common reasons RLS patients seek treatment.4

Prevalence estimates for RLS in the United States range from 2.4 percent to 7.4 percent in adults.5 The wide variation reflects different approaches to diagnosing RLS and defining its frequency and severity, and the fact that many RLS questionnaires do not account for individuals who have conditions with similar symptoms. One study designed to characterize the epidemiology of RLS in the U.S. population (a telephone survey of willing adults who answered questions about RLS) defined RLS as “symptoms occurring at least twice weekly with moderate to severe impact” and found prevalence to be 1.5 percent.3

The etiology of primary RLS is unknown, but the disorder also occurs secondary to other conditions such as iron deficiency, end-stage renal disease, and pregnancy.3 Compared with primary RLS, secondary RLS is less common, often starts later in life and progresses more rapidly, and tends to resolve when the underlying condition is treated or resolved.3 Although mechanistic relationships are yet to be established, the pathophysiology of RLS may be closely linked to abnormalities in the dopaminergic system and iron metabolism.4 The clinical course of RLS varies and commonly includes periods of remission, particularly in younger patients and those with milder disease. Severe RLS, however, is a chronic progressive disorder that may require long-term treatment.4

Treatments (nonpharmacologic and pharmacologic options) vary by patient age, comorbidities, preferences, and disease severity.6 Nonpharmacologic options include: exercise, sleep hygiene, avoiding RLS precipitants (caffeine, alcohol, nicotine, antidepressants, antihistamines); counter stimulus to sensory symptoms (hot or cold baths, limb massage, compression stockings, counter-pulsation devices); herbal medicines and acupuncture; and cognitive behavioral therapy.

Pharmacologic treatment is generally reserved for patients with symptoms that are frequent (typically several times per week) and moderate to very severe. The major classes of drugs used are dopaminergic agents, sedative hypnotic agents, anticonvulsive agents, opiates, and iron. Of these, three dopamine agonists (pramipexole, ropinirole, and rotigotine) and one alpha-2-delta ligands anticonvulsant (gabapentin enacarbil) are U.S. Food and Drug Administration (FDA) approved for treatment of moderate to severe RLS.

A complication of long-term treatment with dopamine agonists is a drug-induced worsening of symptoms known as augmentation, characterized by greater symptom intensity, onset earlier in the day, and shorter latency during inactivity. With augmentation, symptoms may also spread to the arms, trunk, and face.7

The primary goal of RLS treatment is to reduce or eliminate symptoms and improve patient function, sleep, and quality of life. For patients with RLS believed secondary to other conditions (e.g., iron deficiency), treating the underlying condition first is recommended. RLS associated with pregnancy typically resolves postpartum; however, little is known about women with pregnancy-induced RLS whose symptoms persist after delivery.8,9 The authors conducted a systematic review of the effectiveness and harms of treatments for restless leg syndrome with the primary intent to conduct a CER.

The analytic framework adapted from the original draft CER is shown in Figure 1.

Figure 1 Analytic framework

Abbreviations: KQ = Key Question; RLS = restless legs syndrome.

Note: KQ 1: What is the comparative effectiveness of treatments for RLS?

KQ 2: What are the harms of RLS treatments?

KQ 3: What is the effect of patient characteristics on the benefits and harms of treatment for RLS?

Figure 1 depicts how treatments for RLS (KQ1) may contribute to health outcomes in the target population in light of potential modifiers of effect (KQ3) such as age, gender, sex, RLS severity, etiology, comorbidities, iron status, pregnancy and end-stage renal disease. In general, the figure illustrates how treatments for RLS may result in primary outcomes such as change in disease severity and impact on function and secondary outcomes such as quality of life outcomes and patient-reported sleep outcomes. Also, adverse events may occur at any point after the treatment is received (KQ2).

## Findings of the Draft Comparative Effectiveness Review

The literature search conducted for the CER covered the bibliographic databases MEDLINE (via OVID), Embase, and Natural Standards, through September 17, 2011, in order to identify and synthesize data from relevant comparative effectiveness research on treatments for RLS. (Appendix B)

For KQ 1, authors of the draft CER found that randomized controlled trial (RCT) results were limited to short-term efficacy studies versus placebo or usual care (<6 months). Overall high-strength evidence showed that, compared with placebo, dopamine agonists (ropinirole, pramipexole, and rotigotine) reduced RLS symptoms, increased the percentage of patients with a clinically important response (≥50 percent reduction in International Restless Legs Syndrome symptom scale scores or who were “improved” or “much improved” on patient or clinician-reported global impression scale) and improved disease-specific quality of life and patient-reported sleep outcomes. High-strength evidence demonstrated that pregabalin increased the percentage of patients with a clinically important response (≥50 percent reduction in IRLS). Low-strength evidence showed that gamma-aminobutyric acid analogs improved clinician-reported global impression, disease-specific quality of life and patient-reported sleep outcomes compared with placebo. Applicability was limited to nonpregnant, white, middle-aged adults with few comorbidities and RLS symptoms that were long term, frequent, and high-moderate to very severe.

Only three small RCTs addressed nonpharmacologic interventions. (Complete references for these and other indicated studies are available in the full CER.) Pneumatic compression devices reduced IRLS symptom scale scores more than sham (moderate-strength evidence). Strength training and treadmill walking improved IRLS symptoms but adherence was poor and the studies reported results only for study completers. The botanical extract valerian was not effective. Evidence was low strength for all three interventions.

No eligible studies assessed opioids, sedative hypnotics, or tramadol, though these are used clinically for RLS treatment. One study found that the dopamine agonist cabergoline improved scores on the IRLS symptom scale and RLS quality of life scale more than Levodopa (moderate-strength evidence). Carbergoline is not approved for treatment of RLS and has limited use in the United States due to increased risk for cardiac valvular disorders. Observational studies and long-term open-label followup from RCTs of pharmacologic interventions found that withdrawal from treatment at 1 year or more was common ranging from 13 to 57 percent. Reasons for withdrawal were lack of efficacy (6 to 32 percent), and adverse events including augmentation (7 to 62 percent).

For KQ 2, the authors found that study withdrawals (due to any reason) from RCTs were slightly less common in patients randomized to dopaminergic agents than to placebo (moderate-strength evidence). Study withdrawals due to adverse effects were more common (though not statistically so) with dopamine agonist treatment than placebo (low-strength evidence). Differences were primarily due to an increase in withdrawals related to adverse effects (application site reactions) reported in three trials of transdermal rotigotine. More patients randomized to dopamine agonist had at least one adverse effect compared with placebo (high-strength evidence). Short-term adverse effects from treatment with dopamine agonists compared with placebo were nausea, vomiting, and somnolence (high-strength evidence for all these outcomes). Application site reactions were much more common with transdermal rotigotine than with placebo (high-strength evidence).

Some indirect evidence from placebo-controlled trials suggests that fatigue may be more common with ropinirole then pramipexole or rotigotine. Data from observation studies indicates that long-term augmentation ranged from 2.5 percent to 60 percent and varied markedly by type of dopamine agonist, followup time, study design, and method used to ascertain augmentation. The authors found no clear pattern to explain this variability. Withdrawal from mostly dopamine agonist and levodopa treatment was common, occurring in 13 percent to 57 percent of subjects due either to lack of efficacy or adverse effects. Most studies reported treatment withdrawals greater than 20 percent at 1 year.

For KQ 3, the authors found that no RCTs examined the effect of patient or RLS characteristics on benefits and harms of treatments for primary RLS. No RCTs enrolled children or women who were pregnant or recently postpartum, and nearly all specifically excluded these individuals. No eligible studies enrolled individuals with end-stage renal disease, and almost all specifically excluded these individuals. Two small randomized trials of iron therapy versus placebo in adults with iron deficiency provided low-strength evidence that iron may improve IRLS symptom scale scores and possibly the percentage of adults considered IRLS responders.

Nearly all of the pharmacologic trials (dopamine agonist, anticonvulsants, and iron therapies) were considered of good quality (having a low risk of bias). The applicability of the included evidence for RLS treatments is limited. Included studies were mostly short-term, placebo-controlled efficacy studies of dopamine agonists and gamma-aminobutyric acid analogs conducted in a highly selected population of adults with moderate to very severe primary RLS of long-duration. Applicability to adults with less frequent or less severe (mild to moderate) RLS symptoms, children, or those with secondary RLS is unknown. Furthermore, studies did not address long-term effectiveness, the comparative effectiveness and harms of commonly used treatments, or the effect of patient or RLS characteristics on outcomes.

## Objective

This FRNs project identifies and prioritizes specific gaps in the current literature on treatments for RLS that would, if addressed, assist decisionmakers. We used a deliberative process to identify specific research needs along with research design considerations meant to advance the field.

## Evidence Gaps and Research Question Development

As with much of the research on treatments for RLS, many studies of interventions for patients with RLS exhibited problems with design and conduct. Our original report included recommendations to improve future research on this topic. From the draft report we refined and developed the list of evidence gaps listed in the draft report and phrased the gaps as research questions. Discussion with stakeholders led to development of additional preliminary research questions (below). These are separated into two categories: (1) methodological research questions that need to be addressed to enhance the usefulness of current research, and (2) topical research questions that have not been sufficiently addressed within the current literature. Additionally, both recently published studies as well as on-going trials were considered when research gaps were identified (see Appendixes C and D).

### Methodological Research Questions

1. What is the sensitivity/specificity of RLS diagnostic tools?
2. What is the effect of RLS-related chronic sleep deprivation on cardiovascular health?
3. What are the long-term consequences of RLS beyond currently understood sensory problems?
4. What is the causal pathway between RLS and insomnia?
5. What time frames should be studied to establish treatment benefits and harms?
6. Minimum important differences: (a) What IRLS scale score changes translate to clinically meaningful improvement for individual patients?; (b) Is there a correlation between change in IRLS and clinically important change in Clinical Global Impression?; (c) What is the correlation of polysomnography outcomes to remission of symptoms?; (d) What are the minimum outcomes to be reported?; (e)What are the proportions of patients with remission of symptoms (IRLS score = 0), patient reported sleep outcomes, quality of life, etc.?

### Topical Research Questions

1. What environmental factors are associated with RLS? Is there a geographic/environmental predictor?
2. What are the genetic linkages and biomarkers that are associative or diagnostic or causally define RLS?
3. Does tolerance/effectiveness of treatment for RLS vary by demographic/clinical/genetic factors?
4. What is the short- and long-term comparative effectiveness and harms of treatments for RLS?
5. What is the long term effectiveness/comparative effectiveness of alpha 2 ligands for the treatment of RLS?
6. What is the effectiveness of nonpharmacologic therapies for RLS (mind-body, herbs/natural products, energy fields, and manipulation)?
7. How might the progression of RLS be delayed?
8. Does treatment of RLS improve non-RLS comorbidities?
9. Is RLS associated with cardiovascular disease and other health conditions—in particular what is the effect of RLS-related chronic sleep deprivation on cardiovascular health?
10. What is the effectiveness of other drugs that are not dopamine agonists or alpha 2 ligands (e.g., opioids and sedative hypnotics)?
11. Are certain patient characteristics (such as iron deficiency, disease duration, severity) more highly associated with augmentation with dopaminergic therapy?
12. Does treatment efficacy differ by RLS symptom severity?
13. What is the effectiveness of approved RLS drugs on patient subgroups such as children, older adults, and individuals with secondary RLS?
14. How do the findings from published randomized trials apply to patients diagnosed in primary care settings and/or with milder disease of shorter duration?