# Ongoing Trials

NCT Number | Title | Interventions
NCT00373542 | 12-week Polysomnography Study of Ropinirole Controlled Release for RLS | Drug: ropinirole CR-RLS
NCT00256854 | Converting From Ropinirole IR To Ropinirole Controlled-Release for RLS | Drug: ropinirole controlled-release for RLS
NCT01192503 | Safety and Efficacy of Rasagiline in Restless Legs Syndrome | Drug: rasagiline\|Drug: placebo (sugar pill)
NCT00806026 | Long Term Study Of Pregabalin In Idiopathic Restless Legs Syndrome Patients | Drug: placebo and pregabalin
NCT00314860 | Comparing IR Formulation With XR Formulation Of Ropinirole | Drug: ropinirole Extended Release (XR)
NCT01569464 | Rotigotine Effect on Functioning and QOL in Subjects With RLS | Drug: Rotigotine
NCT00363857 | A Clinical Research Study Testing Ropinirole Treatment for RLS | Drug: Ropinirole
NCT00949806 | RLS Treatment With Botulinum Toxin | Drug: BNT (intradermal injection)
NCT00225862 | A Clinical Research Study Evaluating Ropinirole Treatment For RLS | Drug: ropinirole
NCT01245777 | RLS With Iron Deficiency or Anaemia in the 3rd Trimester of Pregnancy | Drug: ferric carboxymaltose
NCT00367822 | Transdermal Lisuride: a Trial for the Treatment of Patients With RLS | Drug: Lisuride; Ropinirole; Placebo
NCT01521663 | Safety and Efficacy Study of IPX159 in RLS | Drug: IPX159; Placebo
NCT00247364 | A Trial of Levetiracetam and Placebo in the Treatment of RLS | Drug: Levetiracetam (Keppra)
NCT00872248 | Neuraxial Anesthesia and RLS in Cesarean | Procedure: Spinal/epidural anesthesia
NCT00355641 | Long-Term Safety Of Ropinirole XR In Patients With RLS | Drug: Ropinirole Extended Release (XR)
NCT01494766 | Efficacy of Tyrosine in RLS | Dietary Supplement: L-Tyrosine
NCT00479531 | Sequential Compression Devices for Treatment of RLS | Device: AirCast Compression Device
NCT00530530 | ASP8825 - Study in Patients With RLS | Drug: ASP8825\|Drug: Placebo
NCT01562743 | A Long-Term Extension Trial From Late Phase II of SPM 962 in Patients With RLS | Drug: SPM 962
NCT00656110 | Neuroma Injections to Treat Restless Legs Syndrome - RCT | Drug: Marcaine; lidocaine; Depo-medrol
NCT00584246 | Pregabalin (Lyrica) for the Treatment of RLS | Drug: Pregabalin (Lyrica); Placebo
NCT00625547 | A Study to Determine the Efficacy and Safety of Cabergoline for the Treatment of Patients With RLS | Drug: cabergoline; levodopa
NCT00239486 | Dose Finding Study of Pramipexole (Sifrol) in Patients With Idiopathic RLS | Drug: Pramipexole
NCT00349531 | A Phase IV Trial With Pramipexole to Investigate the Effects on RLS Symptoms and Sleep Disturbance in Patients With RLS | Drug: Pramipexole
NCT00197080 | Ropinirole XR (Extended Release) In Patients With RLS | Drug: Ropinirole Extended Release (XR)
NCT01537042 | A Sleep Laboratory Study to Investigate the Safety and Efficacy of the Rotigotine Skin Patch in Subjects With RLS and End-Stage Renal Disease Requiring Hemodialysis | Drug: Rotigotine; Placebo
NCT00258492 | RLS Syndrome Exercise Intervention | Behavioral: Aerobic exercise
NCT00136045 | Three Different Transdermal Doses of Rotigotine in Subjects With Idiopathic RLS | Drug: Rotigotine
NCT00135993 | Four Different Transdermal Doses of Rotigotine in Subjects With Idiopathic RLS | Drug: Rotigotine
NCT00685815 | Intravenous Iron Metabolism in RLS | Drug: Ferric Carboxymaltose; Placebo
NCT00200941 | Efficacy and Safety Study of Topiramate to Treat RLS | Drug: Topiramate
NCT00199446 | Study of Istradefylline (KW-6002) for the Treatment of RLS | Drug: Istradefylline (KW-6002)
NCT00942253 | Exercise Training in Dialysis Patients With RLS | Other: Dopamine Agonist and Exercise
NCT01084551 | Study of SPM 962 in Patients With RLS | Drug: SPM 962; Placebo of SPM 962
NCT00498108 | Phase 3 Open-label Extension Trial With Rotigotine in Idiopathic RLS Subjects | Drug: Rotigotine
NCT00626418 | The Effects of Aplindore on the Treatment of Signs and Symptoms of RLS | Drug: Aplindore; Placebo
NCT00263068 | An Extension Trial to Investigate Long-Term Treatment With Rotigotine in Idiopathic RLS | Drug: Rotigotine
NCT01495793 | Dose Escalating Study of Rotigotine in Pediatric Subjects With RLS | Drug: Rotigotine
NCT00666965 | A Placebo-Controlled Study for SPM 962 in RLS Patients | Drug: SPM 962
NCT00243217 | Rotigotine RLS Dose Finding Trial | Drug: SPM 936
NCT00627003 | A Study to Evaluate the Efficacy and Safety of Cabergoline Compared With Placebo for the Treatment of RLS | Drug: Cabergoline; Placebo
NCT00275236 | A Sleep Lab Trial to Investigate the Efficacy and Safety of Transdermal Rotigotine in Subjects With Idiopathic RLS | Drug: Rotigotine
NCT00895232 | Iron Sucrose In The Treatment of RLS: The Safety of Three Dose Regimens as Evaluated by Clinical Assessments | Drug: iron sucrose injection (Venofer)
NCT00298623 | XP13512 (GSK1838262) Versus Placebo in Patients With RLS | Drug: XP13512 (GSK1838262); Placebo
NCT00991276 | Polysomnography Study Of Pregabalin And Pramipexole Versus Placebo In Patients With RLS And Associated Sleep Disturbance | Drug: pregabalin; Placebo; pramipexole
NCT00275457 | Efficacy and Safety of Pramipexole in Moderate to Severe Idiopathic RLS Patients | Drug: pramipexole
NCT00144209 | Swiss RLS Trial | Drug: pramipexole; levodopa & benserazide
NCT00344994 | SWITCH:Restless Legs Patients Switched to Ropinirole From Pramipexole | Drug: pramipexole
NCT01112644 | Oxycodone/Naloxone Prolonged Release (OXN PR) Compared with Placebo to Demonstrate Improvement in Symptoms of RLS in Subjects With Moderate to Severe Idiopathic RLS With Daytime Symptoms | Drug: OXN PR; Placebo
NCT00133198 | Pramipexole (Mirapex®) in Patients With Idiopathic RLS for 12 Weeks | Drug: Pramipexole
NCT01125033 | Study of Vitamin C, Vitamin E and Their Combination to Treat RLS in Hemodialysis Patients | Drug: Vitamin C; Vitamin E; Placebo
NCT00152997 | Pramipexole (BIoSifrol®) Orally Once Daily for 6 Weeks in Patients With Primary RLS | Drug: Pramipexole; Placebo
NCT00356096 | Phase IV Trial With Pramipexole to Evaluate Safety and Efficacy in Patients With RLS Associated With Mood Disturbances | Drug: pramipexole
NCT00375284 | A 6 Week Trial to Study the Efficacy and Safety of a Starting Dose 0.25 mg Pramipexole (Mirapex) in Patients With RLS | Drug: Pramipexole
NCT00152958 | A Study in Patients Suffering From Idiopathic RLS Who Responded to a Preceding, 6-month Treatment With Open-label Pramipexole Including Titration | Drug: Pramipexole
NCT01411124 | Study to Assess the Effect of Gabepentin Enacarbil on Simulated Driving in Healthy Subjects | Drug: gaba enacarbill; diphenhydramine; placebo
NCT00674310 | A Single-Dose, 2-Period, 2-Treatment, 2-Way Crossover Bioequivalency Study of Ropinirole 0.25 mg Tablets Under Fed Conditions | Drug: Ropinirole Hydrochloride
NCT00673088 | A Single Dose, 2-Period, 2-Treatment, 2-Way Crossover Bioequivalency Study of Ropinirole 0.25 mg Tablets Under Fasted Conditions | Drug: Ropinirole Hydrochloride
NCT00246051 | Comprehensive Police Fatigue Management Program | Behavioral: Sleep Hygiene EducationProcedure: Sleep Disorders Screening and Treatment
NCT00207285 | Sleep Disorders Management, Health and Safety in Police | Behavioral: Sleep Hygiene Education Procedure: Screening and Trt of Sleep Disorders
NCT01476124 | Drug Drug Interaction Study With Gabapentin Enacarbil and Morphine | Drug: morphine; Placebo
NCT01516372 | A Study to Evaluate Effect of Gabapentin on Cardiac Repolarization in Healthy Volunteers | Drug: GEn 1200/6000mg; Placebo; Moxifloxacin
NCT00422994 | A Study To Investigate The Effects Of End Stage Renal Disease And Hemodialysis On The Pharmacokinetics Of Ropinirole | Drug: ropinirole dosing for up to 28 days
NCT01455012 | Effects of Neupro on Cardiovascular Observations in Patients With RLS | Drug: Rotigotine; Placebo
NCT00419692 | RLS Patient Study On Absorption, Distribution, Metabolism And Excretion Of Ropinirole And The Effect Of Food | Drug: Ropinirole