# Recently Published Studies

1 Garcia-Borreguero D, Hogl B, et al. Systematic evaluation of augmentation during treatment with ropinirole in restless legs syndrome (Willis-Ekbom disease): results from a prospective, multicenter study over 66 weeks. Movement Disorders. 2012;27(2):277-83. [pmid: 22328464].
2 Inoue Y, Uchimura N, et al. Long-term efficacy and safety of gabapentin enacarbil in Japanese restless legs syndrome patients. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2012;36(2):251-7. [pmid: 22036917].
3 Ma J.-F, Wan Q, et al. Efficacy and safety of pramipexole in chinese patients with restless legs syndrome: results from a multi-center, randomized, double-blind, placebo-controlled trial. Sleep Medicine. 2012;13(1):58-63. [pmid: 22137119].
4 Pullen SJ, Wall CA, et al. Psychiatric comorbidity in children and adolescents with restless legs syndrome: a retrospective study. Journal of Clinical Sleep Medicine. 2011;7(6):587-96. [pmid: 22171196].
5 Tzonova D, Larrosa O, et al. Breakthrough symptoms during the daytime in patients with restless legs syndrome (Willis-Ekbom disease). Sleep Medicine. 2012;13(2):151-5. [pmid: 22281003].