# Search Strategy for Recently Published Studies

Database: Ovid MEDLINE(R) <1946 to July Week 2 2012>

Search Strategy:

1. “restless leg$ syndrome”.mp. (2594)
2. “Ekbom syndrome”.mp. (27)
3. Randomized Controlled Trials as Topic/ (81538)
4. randomized controlled trial/ (331851)
5. random allocation/ (75103)
6. double blind method/ (115894)
7. single blind method/ (16375)
8. clinical trial, phase i.pt. (12356)
9. clinical trial, phase ii.pt. (19723)
10. clinical trial, phase iii.pt. (7155)
11. clinical trial, phase iv.pt. (723)
12. controlled clinical trial.pt. (84651)
13. randomized controlled trial.pt. (331851)
14. multicenter study.pt. (146605)
15. clinical trial.pt. (471476)
16. exp Clinical Trials as topic/ (258001)
17. (clinical adj trial$).tw. (171675)
18. ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw. (113479)
19. PLACEBOS/ (31116)
20. placebo$.tw. (137403)
21. randomly allocated.tw. (13776)
22. (allocated adj2 random$).tw. (16099)
23. or/3–22 (1026914)
24. 1 or 2 (2607)
25. 23 and 24 (401)
26. (case reports or comment or editorial or historical article or letter or news or newspaper article or “review”).pt. (4561959)
27. 25 not 26 (295)
28. Epidemiologic studies/ (5433)
29. exp case control studies/ (562126)
30. exp cohort studies/ (1191069)
31. case control.tw. (61351)
32. (cohort adj (study or studies)).tw. (61929)
33. (Follow up adj (study or studies)).tw. (33137)
34. (observational adj (study or studies)).tw. (31188)
35. Longitudinal.tw. (110733)
36. Retrospective.tw. (214571)
37. cross sectional.tw. (124581)
38. cross-sectional studies/ (143330)
39. 1 or 2 (2607)
40. or/28–38 (1593914)
41. 39 and 40 (477)
42. (case reports or comment or editorial or historical article or letter or news or newspaper article or “review”).pt. (4561959)
43. 41 not 42 (413)
44. 27 or 43 (616)

## Advanced search for Intervention studies on ClinicalTrials.gov

physical therapy or exercise in the intervention field

and (osteoarthritis and knee) in the condition field