# Research Gap Questions for Prioritization

## Treatments for Restless Leg Syndrome Future Research Questions

### Methodological Questions

- What is the sensitivity/specificity of RLS diagnostic tools?
- What is the effect of RLS-related chronic sleep deprivation on cardiovascular health?
- What are the long-term consequences of RLS beyond currently understood sensory problems?
- What is the causal pathway between RLS and insomnia?
- What time frames should be studied to establish treatment benefits and harms?
- Minimum important differences: (a) What IRLS scale score changes translate to clinically meaningful improvement for individual patients? (b) Is there a correlation between change in IRLS and clinically important change in Clinical Global Impression? (c) What is the correlation of polysomnography outcomes to remission of symptoms? (d) What are the minimum outcomes to be reported? (e)What are the proportions of patients with remission of symptoms (IRLS score = 0), patient reported sleep outcomes, quality of life, etc.?

### Topical Questions

- What environmental factors are associated with RLS? Is there a geographic/environmental predictor?
- What are the genetic linkages, biomarkers that are associative, diagnostic or causally define RLS?
- Does tolerance/effectiveness of treatment for RLS vary by demographic/clinical/genetic factors?
- What is the short and long term comparative effectiveness and harms of treatments for RLS?
- What is the long term effectiveness/comparative effectiveness of alpha 2 ligands for the treatment of RLS?
- What is the effectiveness of nonpharmacologic therapies for RLS? (mind-body, herbs/natural products, energy fields, and manipulation).
- How might the progression of RLS be delayed?
- Does treatment of RLS improve non-RLS comorbidities?
- Is RLS a risk factor for cardiovascular disease and other health conditions?
- What is the effectiveness of other drugs that are not dopamine agonists or alpha 2 ligands (e.g. opioids and sedative hypnotics).
- Are certain patient characteristics (iron deficiency or disease duration or severity more highly associated with augmentation with dopaminergic therapy?
- Does treatment efficacy differ by RLS symptom severity?
- What is the effectiveness of approved RLS drugs on patient subgroups such as children, older adults, and individuals with secondary RLS?
- How do the findings from published randomized trials apply to patients diagnosed in primary care settings and/or with milder disease of shorter duration?