# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
EPC: Evidence-based Practice Center
FRN: Future Research Needs
IRLS: International Restless Legs Syndrome Study Group
KQ: Key Question
MCID: Minimum Clinically Important Difference
PICOTS: Population, intervention, comparison, outcome, timing, setting
RCT: Randomized clinical controlled trials
RLS: Restless legs syndrome