# Results

## Research Needs

### Prioritization Results

Stakeholders separately ranked methodological and topical research questions. Of the 14 stakeholders invited to participate in the ranking process, 11 stakeholders ranked methodological research questions and 12 ranked topical research questions. Participating stakeholders primarily identified themselves as physical therapists, but the group also included physicians, an epidemiologist, and a health scientist. We analyzed weighted stakeholder rankings for each research question to identify natural breakpoints (Table 1). High- and moderate-priority methodological research questions and high-priority topical research questions were deemed research needs.

Table 1 Stakeholder prioritization of research gap questions

| Ranking | Total (Points)^*^ | PICOTS Element
Methodological Topics Needing Consensus (n=11) | Tier 1: High Priority
Methodological Topics Needing Consensus (n=11) | Which patient-centered outcome measurement instruments should be used consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)? | 9 (33) | NA
Methodological Topics Needing Consensus (n=11) | Tier 2: Moderate Priority
Methodological Topics Needing Consensus (n=11) | Should effectiveness research on PT treatments use minimal clinically important differences? | 7 (21) | NA
Methodological Topics Needing Consensus (n=11) | What confounding and effect modifying variables (e.g. OA severity, obesity, comorbidities, and concomitant therapies including anti-inflammatory and analgesic medication) should be measured and reported in effectiveness research? | 6 (18) | NA
Methodological Topics Needing Consensus (n=11) | Which intermediate outcome measurement instruments should be used consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)? | 5 (15) | NA
Methodological Topics Needing Consensus (n=11) | What minimum set of treatment factors (site, treatment components, frequency, duration, intensity, timing) should be reported consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)? | 5 (13) | NA
Methodological Topics Needing Consensus (n=11) | Tier 3: Low Priority
Methodological Topics Needing Consensus (n=11) | How should multimodal PT treatments be classified? | 2 (8) | NA
Methodological Topics Needing Consensus (n=11) | How should knee OA severity be graded consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)? | 1 (3) | NA
Topical Questions Needing Trials (n=10) | Tier 1: High Priority
Topical Questions Needing Trials (n=10) | Which PT treatments work for which patients? | 7 (22) | P, I
Topical Questions Needing Trials (n=10) | How do the duration, intensity, and frequency of examined interventions affect sustained changes in patient-centered outcomes? | 7 (18) | I
Topical Questions Needing Trials (n=10) | What is the comparative effectiveness of comprehensive multimodal PT treatments on patient-centered outcomes when compared with exercise alone? | 5 (15) | I
Topical Questions Needing Trials (n=10) | In individuals who proceed to joint replacement surgery, do patients who underwent PT treatments prior to surgery fare better postoperatively? | 6 (14) | P
Topical Questions Needing Trials (n=10) | Tier 2: Moderate Priority
Topical Questions Needing Trials (n=10) | Do periodic followup treatments beyond the initial PT treatments enhance effectiveness? | 5 (10) | NA
Topical Questions Needing Trials (n=10) | What is the long-term effectiveness of PT treatments on patient centered outcomes? | 3 (10) | NA
Topical Questions Needing Trials (n=10) | What is the comparative effectiveness over the entire course of different comprehensive multimodal PT programs (from initial PT-directed treatments through self-management and occasional followup treatments)? | 3 (8) | NA
Topical Questions Needing Trials (n=10) | Tier 3: Low Priority | | NA
Topical Questions Needing Trials (n=10) | How does the method of delivery (e.g., the involvement of a physical therapist or physical therapist assistant, group versus individual exercise, self-administered versus supervised exercises, etc.) affect patient-centered outcomes? | 3 (3) | NA
Topical Questions Needing Trials (n=10) | Does PT for knee OA delay time to surgery? | 2 (3) | NA
Topical Questions Needing Trials (n=10) | Does PT for knee OA reduce medication use? | 1 (1) | NA
Topical Questions Needing Trials (n=10) | Do PT treatments affect structural joint changes? | 1 (1) | NA

NA = Not applicable; OA = osteoarthritis; PICOTS = population, intervention, comparison, outcome, timing, and setting; PT = physical therapy

* Rankings were weighted to create a total point score by assigning questions ranked #1 by stakeholders with 4 points, questions ranked #2 with 3 points, questions ranked #3 by stakeholders with 2 points, and questions ranked #4 by stakeholders with 1 point.

### Methodological Research Needs

From among the methodological questions, the identification of a standard set of patient-centered outcomes measures was a clear frontrunner (Tier 1: High Priority), with more than 70 percent of stakeholders ranking it a priority and over half of all stakeholders ranking it the number-one priority. The rankings of four additional methodological research gap questions were clustered together, but distantly less important to stakeholders than the top tier (Tier 2: Moderate Priority). Because only one methodological research gap question appeared to be a high priority according to the natural breakpoint in the rankings, we also considered the moderate priority research gap questions to be research needs. Addressing methodological research needs will enhance the utility and translation of current and future research on PT interventions for patients with knee pain secondary to OA.

- Which patient-centered outcome measurement instruments should be used consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?
- Which intermediate outcome measurement instruments should be used consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?
- Should effectiveness research on PT treatments use MCIDs?
- What confounding and effect modifying variables (e.g., OA severity, obesity, comorbidities, and concomitant therapies including anti-inflammatory and analgesic medication) should be measured and reported in effectiveness research?
- What minimum set of treatment factors (site, treatment components, frequency, duration, intensity, timing) should be reported consistently by all relevant disciplines (e.g., PT, rheumatology, orthopedics)?

Methodological research needs pertain to how effectiveness is measured and the consistency, completeness, and reporting of intervention studies for knee pain secondary to OA. The first three research needs reflect the need for consensus on how to best measure effectiveness. Pain and function are considered important patient-centered outcomes for adults with knee OA. PT interventions for knee OA should be evaluated for the degree to which they can improve function and decrease pain. Prior to the stakeholder ranking process, we assumed general agreement about which patient-centered and intermediate outcome measurement instruments should be used in effectiveness research. CER authors and stakeholder discussions appeared to indicate that preferred measures were generally understood. Several stakeholders mentioned the Outcome Measures in Rheumatology recommended set of outcomes measures for future hip, knee, and hand trials.19 Despite this available guidance, the CER and other OA research demonstrate the use of a wide variety of outcomes measures.14,20

The CER emphasized that relatively few studies used MCIDs in evaluating efficacy and effectiveness. However, stakeholder discussions described problems with relying on MCIDs. Theoretically, MCIDs offer a way to meaningfully interpret scale scores; however, the validity and utility of MCIDs are impeded by issues surrounding their calculation, reliability, and applicability to specific research populations, and by the use of an average score to evaluate effectiveness for all patients.

Literature examined for the draft CER rarely provided adequate and consistent measurement and reporting of variables thought to confound or modify the effect of PT treatments for knee OA. Related to the reporting of confounding and effect modifying variables, stakeholders would like to see consensus on how studies should report specific intervention characteristics.

#### Considerations for Potential Research Designs

Methodological research needs could be addressed through a consensus development process (i.e. consensus conference). Because knee OA is treated by more than one group of providers, an ideal consensus development process would be multidisciplinary, with representation from clinical areas (PT, rheumatology, and orthopedics) and researchers with expertise in clinical outcomes, epidemiology, biostatistics, and health services research. Continuing consensus work, facilitated by the Osteoarthritis Research Society International and Outcome Measures in Rheumatology, on improving the reporting and measuring effectiveness in OA trials20 will offer valuable information to address this research need. Specific research needs, such as guidance in the use of MCIDs, may benefit from prework prior to the consensus development process. The information necessary for facilitating a discussion on MCIDs could be identified, collected or generated, and distributed before discussion.

### Topical Research Needs

We identified four high-priority topical research gap questions as research needs and highlighted the PICOTS element(s) addressed for each need (Table 1). All topical research needs addressed primarily populations and interventions. Addressing topical research needs will enhance understanding of efficacy and comparative effectiveness, which was limited in our recently completed CER. New research addressing topical questions will provide improved information for decisionmakers.

#### First Topical Research Need

- Which PT treatments work for which patients?

The draft CER, other reviews on the topic, current efficacy studies, and stakeholder discussions emphasized the need to address efficacy and comparative effectiveness for particular types of patients. While specific subgroups and interventions were not specified in this research need, subgroups can likely be defined by prevalent patient characteristics such as age, degree of symptoms, severity of disease, the presence of obesity and other comorbidities that appear to have an effect on response to treatment.

##### Research Design Considerations

Topical research needs are best addressed with experimental designs. However, identifying specific patient subgroups (hypothesis generating research) may first be accomplished with less rigorous research designs. Review of previous systematic reviews, published trials including post hoc subgroup analyses, observational studies, and administrative databases could be used to extract hypothesized relationships between patient characteristics and specific therapies or multimodal treatments. The systematic review found very little evidence testing particular interventions for specific types of patients since very few studies reported the treatment outcomes for specific patient subpopulations. The systematic review focused on randomized controlled trials which can provide valid treatment estimates equally distributing patient characteristics and concomitant treatments among treatment groups. However, the review concluded that the results are applicable to the target population and much less to the subpopulations by age, gender, baseline OA severity, and response to pharmacological treatments. Therefore, future research is needed for hypotheses by garnering expert opinion about which patient subgroups may respond differently to specific therapies.

Once hypotheses are generated, they should be tested using rigorous experimental design. Randomized controlled trials (RCTs) are the best approach. Conducting RCTs on specific patient subgroups is feasible yet the systematic review found very weak evidence of treatment effects in patient subpopulations. The review concluded that the evidence from individual RCTs did not support robust conclusions about differences in PT effects by patient age, gender, baseline severity of knee OA and multijoint OA, or responses to prior PT and drug treatments. However, a more valuable study design would be a large scale RCT with representative samples of sufficient size (as determined by the appropriate power calculations) from various subgroups of patients identified a priori. In designing these trials, another important concern lies in defining the PT treatments. Treatment definition for the intervention and comparator should be sufficient to explain specific activities used in each PT session or a protocol that explains the sequence of therapies. Treatments compared should capture the full range of PT treatments that would be used in practice. Fidelity checks may be necessary to monitor compliance with protocols. Attention should be paid to other concomitant treats, especially anti-inflammatory drugs and analgesics. Table 2 provides more detailed research design considerations relevant to this research need.

Table 2 First topical research need: research design considerations

Research Question: Which PT treatments work for which patients?
Considerations | RCT
Design Description | Groups of adults with knee OA randomly assigned to either exercise alone or multimodal program and followed over time to determine improvement in outcomes as response to treatment. Patient and disease characteristics can be tested to examine influence on response to treatment.
Population | A diverse group of patients with knee OA (diverse in terms of patient and disease characteristics). Subgroups defined by patient age, severity of OA, multi-joint OA, prior and concomitant treatments, comorbidities, etc.
Intervention | PT interventions hypothesized to improve response in specific groups of patients.
Comparator | Standard treatment: exercise alone.
Outcomes | Clinically important differences in pain, independence in ADL, patient satisfaction, quality of life, psychological disability, self-perceived health, time to surgery, postsurgical outcomes.
Timing | Followup that extends beyond treatment duration would add value to currently available knowledge.
Setting | PT practices.
Advantages for Producing a Valid Result | Randomization produces the most valid results. Recruitment that includes sufficient numbers of patients in select subgroups allows sample to better reflect real world patients enhancing generalizability. Investigators need to conduct power calculations to recruit sufficient stratified samples.
Resource use, size and duration | Resource use is high. A large sample will be required and follow-up should extend beyond treatment duration.
Ethical, legal, and social issues | Ethical issues are minimal; interventions are non-invasive and harms not life-threatening.
Availability of data/ability to recruit | Not likely to be an issue given the prevalence of knee OA.

ADL = activities of daily living; OA = osteoarthritis; PT = physical therapy; RCT = randomized controlled trial

#### Second Topical Research Need

- How do the duration, intensity, and frequency of examined interventions affect sustained changes in patient-centered outcomes?

The CER found limited evidence to evaluate intervention characteristics. The duration of examined PT interventions was not consistently associated with better intermediate or patient-centered outcomes. Evidence regarding the association between the dose/intensity/frequency of examined interventions and outcomes was not available for the majority of comparisons. The effects of the treatments that significantly improved outcomes, including exercise (aerobic, aquatic, and strengthening) and ultrasound did not differ at shorter versus longer followup times. Moreover, electrical stimulation worsened pain at longer followup. Study risk of bias and heterogeneity in populations and treatments including concomitant treatments hampered strength of evidence to low or moderate in most cases. Stakeholder discussions confirmed that a better understanding of different intervention characteristics (especially dosage) and how they influence effectiveness would better inform decisionmaking.

##### Research Design Considerations

Processes similar to those mentioned above could be used to identify specific intervention characteristics that contribute to effectiveness. Again, experimental designs are likely the best approach to testing hypothesized relationships, yet very few RCTs examine the role of treatment intensity and duration on patient centered outcomes. The review found no high quality observational studies or administrative databases analyses suggesting significant improvement in patient centered outcomes with longer and more intense PT interventions in adult with knee OA. Design considerations for these experimental studies are also similar to those of this first research need. The approach might be implemented with trials testing the standard evidence-based treatment, exercise therapy. The most valid way to then address this research need would be with RCTs; however it may prove difficult to mount studies of adequate size. In that case quasi-experimental designs may be necessary. Prospective cohort studies with large samples may be preferred to small RCTs, yet no well designed prospective cohort analyzed the association between PT intensity and duration on paid, function, or disability in older adults with knee OA. In either case, investigators should be careful to appropriately define the PT treatment and document the intensity, duration, and frequency. Special attention should be paid to adherence among study participants. Studies should be sufficiently powered to detect differences between groups as determined by appropriate power calculation. A major concern is in powering the study adequately to test the effects of combinations of treatment variations. The cohort studies should pay additional attention to identifying and adjusting results for potentially confounding variables. Table 3 provides more detailed research design considerations for this research need.

Table 3 Second topical research need: research design considerations

Research Question: How do the duration, intensity, and frequency of examined interventions affect sustained changes in patient-centered outcomes?
Considerations | RCT | Prospective Cohort
Design description | Groups of adults with knee OA randomly assigned to exercise therapy at varying levels of intensity, frequency, and duration and followed over time to determine improvement in outcomes as response to treatment. Intervention characteristics can be tested to examine influence on response to treatment. | Prospectively designed cohorts of individuals with knee OA receiving exercise therapy at varying levels of intensity, frequency, and duration and followed over time to determine improvement in outcomes as response to treatment. Intervention characteristics can be tested to examine influence on response to treatment.
Population | Adult patients with knee OA. | Adult patients with knee OA.
Intervention | PT interventions with duration, intensity, and frequency different from standard/average. | PT interventions with duration, intensity, and frequency different from standard/average.
Comparator | PT interventions with standard (average) duration, intensity, frequency. | PT interventions with standard (average) duration, intensity, frequency.
Outcomes | Clinically important differences in pain, independence in ADL, patient satisfaction, quality of life, psychological disability, self-perceived health time to surgery, postsurgical outcomes. | Clinically important differences in pain, independence in ADL, patient satisfaction, quality of life, psychological disability, self-perceived health time to surgery, postsurgical outcomes.
Timing | Follow-up that extends beyond treatment duration would add value to currently available knowledge. | Follow-up that extends beyond treatment duration would add value to currently available knowledge.
Setting | PT practice. | PT practice.
Advantages for producing a valid result | Randomization allows for most valid results. Interventions should be adequately defined. RCTs need to be sufficiently powered to detect differences between groups as determined by appropriate power calculations. Investigators should not impose overly strict inclusion criteria that would hamper generalizability. | Enables recruitment of larger samples. Allows inclusion of real world patients which enhances generalizability. Investigators will need to collect data on known confounders and statistically adjust in analysis.
Resource use, size and duration | Resource use is high. A large sample will be required and follow-up should extend beyond treatment duration. | Resource use is moderate. A large sample will be required and follow-up should extend beyond treatment duration.
Ethical, legal, and social issues | Ethical issues are not a concern because interventions are typical care. | Ethical issues are not a concern because interventions are typical care.
Availability of data/ability to recruit | Not likely to be an issue given the prevalence of Knee OA. | Not likely to be an issue given the prevalence of Knee OA. Prospective approach allows all relevant data to be collected.

ADL = activities of daily living; OA = osteoarthritis; PT = physical therapy; RCT = randomized controlled trial

#### Third Topical Research Need

- What is the comparative effectiveness of comprehensive multimodal PT treatments on patient-centered outcomes when compared with exercise alone?

The two remaining research needs have more focused hypotheses. Few studies comparing multimodal treatments to exercise alone are available, yet this question is particularly important to informing clinical practice. Current guidelines recommend that PT be delivered with a combination of modalities. Published research has focused instead on the marginal effects of individual PT interventions. The systematic review concluded that the studies overall had low applicability to the actual practice of PT because available studies focused on single modalities of PT rather than the combinations typically used in practice. In addition, many of the interventions were physical agents/modalities (i.e., orthotics, ultrasound, taping, etc.). This also contradicts the recommended practice of PT, in which physical agents/modalities are infrequently used in isolation, but rather combined with other more “active” interventions (i.e., exercises). The review found that few studies of combined PT modalities demonstrated no statistically significant benefit on the outcomes when compared with exercise alone.

##### Research Design Considerations

Given the specific hypothesis of this research need, an RCT is likely the best approach. Randomization eliminates concerns about inherent differences between the groups assigned to each intervention being responsible for differences in outcomes. An RCT will be resource intensive, requiring a large sample size because the marginal difference between the two active treatment arms is likely to be low and subgroups are particularly relevant in this question. Investigators should pay careful attention to defining the multimodal programs; only a limited number of combinations will be feasible. Table 4 describes research design considerations for this research need in more detail.

Table 4 Third topical research need: research design considerations

Research Question: What is the comparative effectiveness of comprehensive multimodal physical therapy treatments on patient-centered outcomes when compared with exercise alone?
Considerations | RCT
Design Description | Individual patients randomly assigned to one of two PT treatments, randomization stratified by patient age, baseline OA severity, prior and concomitant treatments, comorbidities (patient subgroups hypothesized to benefit from multimodal therapy).
Population | Patients with knee pain secondary to OA.
Intervention | Multimodal PT program.
Comparator | Exercise therapy alone.
Outcomes | Clinically important changes in pain, independence in ADL, patient satisfaction, quality of life, psychological disability, self-perceived health.
Timing | 3–6 months, or consider longer follow-up to address other research gaps.
Setting | PT clinic.
Advantages for Producing a Valid Result | This design is likely to produce the most valid results. However, inclusion criteria should not be overly strict impairing generalizability.
Resource use, size and duration | Likely necessary to recruit large samples because marginal clinically important difference from one approach vs. another is likely to be low and sampling should be stratified to incorporate subgroup analysis.
Ethical, legal, and social issues | Ethical challenges should be minimal; intervention is non-invasive and potential harms are not life-threatening.
Availability of data/ability to recruit | Not likely to be an issue given the prevalence of knee OA.

ADL = activities of daily living; OA = osteoarthritis; PT = physical therapy; RCT = randomized controlled trial

#### Fourth Topical Research Need

- In individuals who proceed to joint replacement surgery, do patients who underwent PT treatments prior to surgery fare better postoperatively?

The CER focused on community-dwelling adults with knee pain secondary to OA. While many patients with knee OA eventually undergo joint replacement surgery, postsurgical outcomes were beyond the scope of this review. Stakeholders brought up this question as a research gap. Benefits of presurgical PT treatments on patient outcomes after surgery remain unclear and this information would have important clinical implications.

##### Research Design Considerations

In first addressing this research need, investigators should examine previous literature to determine if studies that address this question are available. Once hypotheses are generated, more rigorous studies can be conducted. Due to the potentially long-term nature of this outcome and the difficulty in identifying group members a priori, an RCT or other prospective design may not be feasible. Therefore, testing the hypothesis that individuals receiving PT treatment fare better after knee replacement surgery might best be approached with case control studies. Large sample sizes and the identification, measurement, and appropriate adjustment for confounding variables with multivariate analysis would strengthen the internal validity of these studies. However, limited causal inference will be a limitation. Table 5 describes more detailed research design considerations for this research needs.

Table 5 Fourth topical research need: research design considerations

Research Question: In individuals who proceed to joint replacement surgery, do patient who underwent PT treatments prior to surgery fare better postoperatively?
Considerations | Case Control
Design description | Participants recently undergoing knee replacement surgery are selected and categorized by whether they had PT treatments prior to surgery.
Population | Adults recently undergoing knee replacement surgery.
Intervention | PT interventions prior to surgery.
Comparator | No PT interventions prior to surgery.
Outcomes | Time to surgery, surgical outcomes (e.g. pain, mobility, time to return to activities of daily living, rehabilitation progress, etc.).
Timing | Short.
Setting | PT clinics/surgery centers/rehabilitation.
Advantages for producing a valid result | Results will be most valid with a large sample size and the collection of many potentially confounding variables used to statistically adjust multivariate analysis. Causal inference will be limited.
Resource use, size and duration | Significantly less than nested case control study or a prospective design.
Ethical, legal, and social issues | No ethical challenges anticipated.
Availability of data/ability to recruit | Not likely to be an issue given the prevalence of knee OA and knee replacement surgeries. Combining data from different geographic locations should be explored.

OA = osteoarthritis; PT = physical therapy

### Ongoing Studies

Recently published or ongoing studies may provide information relevant to these topical research needs. Searches for these studies identified 38 recently published studies and 112 ongoing studies. Screening identified seven relevant newly published studies and 83 recent or ongoing trials with at least one arm relevant to identified research gaps (Appendix D). However, few specifically addressed the topical research needs we have identified. Two trials addressing the comparative effectiveness between manual therapy and exercise therapy were identified in our search for ongoing studies. The first (NCT00988468) was terminated due to an inability to recruit a sufficient number of participants.21 The second (NCT01314183) is a four-arm trial comparing supervised exercise alone to exercise plus manual therapy, exercise plus booster sessions after the initial course of treatment, and exercise and manual therapy plus booster sessions after the initial course of treatment.21 This RCT will provide valuable evidence to address the manual therapy versus supervised exercise research need. This study also has the potential to address other lower priority research questions (regarding long-term effectiveness and booster sessions). The trial has a planned sample size of 300.