# References

1 Lawrence RC, Felson DT, Helmick CG, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part II. Arthritis & Rheumatism. Jan. 2008;58(1):26-35. [pmid: 18163497].
2 Johnson CA. Chapter 12 Approach to the Patient with Knee Pain. Imboden JB, Hellmann DB, Stone JH, editors. CURRENT Rheumatology Diagnosis & Treatment. 2e. The McGraw-Hill Companies, Inc. 2007.
3 Jordan JM, Helmick CG, Renner JB, et al. Prevalence of knee symptoms and radiographic and symptomatic knee osteoarthritis in African Americans and Caucasians: the Johnston County Osteoarthritis Project. Journal of Rheumatology. Jan. 2007;34(1):172-80. [pmid: 17216685].
4 Dillon CF, Rasch EK, Gu Q, et al. Prevalence of knee osteoarthritis in the United States: arthritis data from the Third National Health and Nutrition Examination Survey 1991–94. Journal of Rheumatology. Nov. 2006;33(11):2271-9. [pmid: 17013996].
5 Oliveria SA, Felson DT, Reed JI, et al. Incidence of symptomatic hand, hip, and knee osteoarthritis among patients in a health maintenance organization. Arthritis Rheum. Aug. 1995;38(8):1134-41. [pmid: 7639811].
6 Felson DT, Zhang Y, Hannan MT, et al. The incidence and natural history of knee osteoarthritis in the elderly. The Framingham Osteoarthritis Study. Arthritis Rheum. Oct. 1995;38(10):1500-5. [pmid: 7575700].
7 Bernstein AB, Hing E, Moss AJ, et al. Health care in America: Trends in utilization. Hyattsville, Maryland. National Center for Health Statistics. 2003.
8 Imboden J. Chapter 4 Approach to the Patient with Arthritis. Imboden JB, Hellmann DB, Stone JH, editors. CURRENT Rheumatology Diagnosis & Treatment. 2e. The McGraw-Hill Companies, Inc. 2007.
9 National Collaborating Centre for Chronic Conditions. Osteoarthritis: national clinical guideline for care and management in adults. Royal College of Physicians. London. 2008.
10 Richmond J, Hunter D, Irrgang J, et al. American Academy of Orthopaedic Surgeons clinical practice guideline on the treatment of osteoarthritis (OA) of the knee. Journal of Bone & Joint Surgery - American Volume. Apr. 2010;92(4):990-3. [pmid: 20360527].
11 Zhang W, Nuki G, Moskowitz RW, et al. OARSI recommendations for the management of hip and knee osteoarthritis: part III: Changes in evidence following systematic cumulative update of research published through January 2009. Osteoarthritis & Cartilage. Apr. 2010;18(4):476-99. [pmid: 20170770].
12 American Physical Therapy Association. Guide to physical therapist practice. 2nd ed. Alexandria, Va. American Physical Therapy Association. 2001.
13 Pisters MF, Veenhof C, van Meeteren NLU, et al. Long-term effectiveness of exercise therapy in patients with osteoarthritis of the hip or knee: a systematic review. Arthritis & Rheumatism. Oct. 15. 2007;57(7):1245-53. [pmid: 17907210].
14 Shamliyan TA, Wang S-Y, Olson-Kellogg B, Kane RL. Physical Therapy Interventions for Knee Pain Secondary to Osteoarthritis. Comparative Effectiveness Review No. 77. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-2007-10064-I.) AHRQ Publication No. 12(13)-EHC115-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
15 O’Haire C, McPheeters M, Nakamoto EK, et al. Methods for Engaging Stakeholders To Identify and Prioritize Future Research Needs. Methods Future Research Needs Report No. 4. (Prepared by the Oregon Evidence-based Practice Center and the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 11-EHC044-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
16 Effective Health Care Program. Effective Health Care Contacts Database. 2012.
17 SurveyMonkey.com LLC. Palo Alto, California, USA. 2012. www.surveymonkey.com.
18 Carey T, Sanders GD, Viswanathan MT, et al. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
19 Bellamy N, Kirwan J, Boers M, et al. Recommendations for a core set of outcome measures for future phase III clinical trials in knee, hip, and hand osteoarthritis. Consensus development at OMERACT III. Journal of Rheumatology. Apr. 1997;24(4):799-802. [pmid: 9101522].
20 Riddle DL, Stratford PW, Singh JA, et al. Variation in outcome measures in hip and knee arthroplasty clinical trials: a proposed approach to achieving consensus. Journal of Rheumatology. Sep. 2009;36(9):2050-6. [pmid: 19738212].
21 Clinicaltrials.gov. Enhancing the Effectiveness of Physical Therapy for People With Knee Osteoarthritis. clinicaltrials.gov/ct2/results?term=NCT01314183. Accessed on May 8 2012.
22 Boutron I, Moher D, Altman DG, et al. Extending the CONSORT statement to randomized trials of nonpharmacologic treatment: explanation and elaboration. Ann Intern Med. 2008;148(4):295-309. [pmid: 18283207].
23 Des Jarlais DC, Lyles C, Crepaz N, et al. Improving the reporting quality of nonrandomized evaluations of behavioral and public health interventions: the TREND statement. Am J Public Health. Mar. 2004;94(3):361-6. [pmid: 14998794].
24 Office of Management and Budget. Standards and guidelines for statistical surveys. 2006. www.whitehouse.gov/sites/default/files/omb/inforeg/statpolicy/standards_stat_surveys.pdf. Accessed on May 16 2012.