# Stakeholders

- Roy D. Altman, M.D.
  Department of Rheumatology
  UCLA Medical Center
  Los Angeles, CA
- Dale Avers, P.T., D.P.T., Ph.D.
  Physical Therapy
  College of Health Professions
  Syracuse, NY
- Greg A. Brown, M.D.
  Orthopaedic Surgery
  University of Minnesota
  Minneapolis, MN
- Gail Deyle, P.T., D.Sc., D.P.T., O.C.S., FAAOMPT
  Army-Baylor University
  San Antonio, TX
- D. T. Felson, M.D.
  Arthritis Center/Rheumatology
  Boston University School of Medicine
  Boston, MA
- Mark Haubner
  Arthritis Foundation
  Aquebogue, NY
- Jennifer Hootman, Ph.D., A.T.C.
  Division of Adult and Community Health
  Centers for Disease Control and Prevention
  Atlanta, GA
- James Irrgang, Ph.D., P.T., A.T.C.
  University of Pittsburgh
  Pittsburgh, PA
- Lyndon Joseph, Ph.D.
  Division of Geriatrics and Clinical Gerontology
  National Institutes of Health
  Bethesda, MD
- Robin Katzanek, P.T., M.A., Ph.D.
  Liberty Physical Therapy
  Wakefield, RI
- Tim Kauffman, P.T., Ph.D.
  Kauffman Physical Therapy
  Lancaster, PA
- Alan Linblad, P.T., O.C.S.
  Park Nicollet
  Minneapolis, MN
- Susan M. Miller, M.D.
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Carol A. Oatis, P.T., Ph.D.
  Department of Physical Therapy
  Arcadia College
  Glenside, PA
- Jim Panagis, M.D., M.P.H.
  National Institute of Arthritis and Musculoskeletal and Skin Disease
  Bethesda, MD
- Karen Siegel, P.T., M.A.
  Food and Drug Administration
  Silver Spring, MD
- Lynn Snyder-Mackler, P.T., A.T.C., S.C.S., Sc.D.
  Department of Physical Therapy
  University of Delaware
  Newark, DE
- Rita Wong, Ed.D., P.T.
  Department of Physical Therapy
  Marymount University
  Arlington, VA