# Discussion

This FRN project refined and prioritized research needs relevant to the KQs addressed in the draft CER, “Physical Therapy Interventions for Knee Pain Secondary to Osteoarthritis.”14 We developed a set of research questions from evidence gaps identified in the CER. Research gaps included methodological issues that limited the utility of the current research and topical questions that limited conclusions about efficacy and comparative effectiveness of PT treatments. We conducted a deliberative process to refine and expand our set of research gap questions through conversations with stakeholders who represented diverse perspectives of expertise on the topic. Our stakeholder group included physical therapists, orthopedists, rheumatologists, patient advocates, academics, third party payers, funders of related research, and patients. Many stakeholders offered two or more perspectives. This process identified seven methodological and 11 topical research questions. Stakeholders then ranked research questions, and the most highly ranked questions were deemed research needs.

Addressing methodological research needs will enhance the utility and comparability of future studies of PT treatments for knee OA. A common set of patient-centered and intermediate outcomes, with guidance on interpreting changes in outcomes scale scores, will provide researchers with concrete approaches to collecting outcomes data and determining effectiveness. The quality of the literature would be further enhanced if a multidisciplinary panel were to create consensus guidance on how research studies should define PT interventions and report specific variables. Research on this topic will advance when guidance from consensus recommendations is utilized and an evidence base of comparable studies becomes available.

Topical research needs demonstrate the importance of understanding that all PT interventions may not be ideal for all patients. To advance the field, research needs to address which treatments are effective for which patients. Identifying these patterns will provide clinically meaningful implications which can be used to design guidelines for treating patients with knee OA. A better understanding of how PT treatments are defined is essential to understanding their effectiveness. We need to know not only the type of therapy used but also the specific activities conducted, the level of supervision, and the exact frequency and duration. Complete definitions of interventions will enhance the internal validity of studies and allow for replicability of effective treatments. Testing specific hypotheses will fill the evidence gaps identified and prioritized by our stakeholders.

Future studies on PT interventions should attend closely to reducing bias as much as possible for the particular research design used. Further, researchers should conduct studies with adequate power to test hypothesized relationships. Attention to reporting standards using the Consolidated Standards of Reporting Trials (CONSORT) statement for nonpharmacologic interventions could guide the data collected and reported in effectiveness research.22 This statement specifically describes elements of interventions that should be included. The Transparent Reporting of Evaluations with Nonrandomized Designs (TREND) statement, designed for public health interventions, also provides a good explanation of the types of information about interventions that should be captured and reported.23

This FRN project benefited from the multidisciplinary perspective brought by broad stakeholder participation. However, our inability to collect a representative perspective from a larger sample of stakeholders is also our primary limitation. Although the stakeholders participating in this project represented various perspectives on knee OA and PT, the prioritized research needs reflect the opinions of these stakeholders and may not be generalizable to the population of stakeholders on this topic. The sample size was limited by standards and guidelines for statistical surveys administered by the Office of Management and Budget requiring compliance with the Paperwork Reduction Act and Information Collections Policy (44 USC 3501-3520).24 The Act was designed to minimize the paperwork burden on the public, assure that high quality data are obtained, and minimize costs. However, the approval process to allow greater than nine nongovernment participants exceeded the length of time available to complete this project.

Another limitation stems from the structure of the research questions posed to fill evidence gaps. Topical questions that were ranked highly were broader questions that did not specify specific populations or intervention characteristics that future research should address. Questions that were more specific, such as those that asked about the efficacy and comparative effectiveness with respect to certain outcomes, were not ranked high priority. While this may be an indication about the state of the research in the field (i.e., the identification and measurement of patient-centered outcomes and the measures used has received more attention than identifying and testing efficacy and comparative effectiveness with respect to certain subpopulations or elements of interventions). These lower priority research questions could be addressed in studies designed primarily to address the research needs (e.g., by including the specific outcomes measure or increasing the follow time). While the specificity of the research questions may reflect the current state of research in the field with respect to certain PICOTS elements, they could also reflect stakeholder assumptions that the broader questions could in fact also answer the more specific questions.